# Results

Inter-rater reliability testing results are presented first for each of the four domains. We specify the results separately for RCTs and observational studies. These findings are followed by results for the overall strength of evidence.

As shown in Table 5, across independent reviewers and reconciled pairs, the level of agreement (AC1) for domain scores was generally better in their evaluations of RCTs than observational studies. Likely because of the small sample sizes, only one of the comparisons of differences in level of agreement between RCTs and observational studies reached statistical significance. This occurred for risk of bias domain evaluations by both individual reviewers and pairs, as shown by nonoverlapping confidence intervals.

Table 5 Inter-rater reliability results by domain and overall grade

Domain/Strength of Evidence | Study Design | Number of Exercises | AC1 (95% CI) | Percentage (SD) Describing Rating as Difficult or Very Difficult | Correlation Between Ratings on Agreement and Difficulty | Agreement Across Reconciled Pairs of Reviewers: AC1 (95% CI)
Risk of bias | RCT | 10 | 0.67(substantial) (0.61 to 0.73) | 3.2% (3.1%) | r=0.21 | 0.65 (substantial) (0.56 to 0.73)
Risk of bias | Observational | 6 | 0.11 (slight) (0.05 to 0.18) | 9.8% (6.0%) | r=−0.33 | 0.22 (fair) (0.13 to 0.32)
Consistency | RCT | 10 | 0.51 (moderate) (0.34 to 0.67) | 8.7% (9.0%) | r=−0.92 | 0.70 (substantial) (0.51 to 0.90)
Consistency | Observational | 6 | 0.40 (fair) (0.13 to 0.66) | 6.1% (8.0%) | r=−0.74 | 0.55 (moderate) (0.22 to 0.89)
Directness | RCT | 10 | 0.73 (substantial) (0.60 to 0.87) | 4.1% (4.0%) | r=0.09 | 0.78 (substantial) (0.64 to 0.92)
Directness | Observational | 6 | 0.48 (moderate) (0.32 to 0.64) | 6.1% (8.5%) | r=−0.80 | 0.78 (substantial) (0.52 to 1.02)
Precision | RCT | 10 | 0.23 (fair) (0.11 to 0.35) | 17.8% (8.4%) | r=0.24 | 0.47 (moderate) (0.17 to 0.77)
Precision | Observational | 6 | 0.31 (fair) (0.06 to 0.56) | 14.5% (3.4%) | r=0.09 | 0.38 (fair) (0.06 to 0.70)
Strength of Evidence | All exercises | 10 | 0.20 (slight) (0.16 to.25) | 19.6% (11.0%) | r=0.06 | 0.24 (fair) (0.14 to 0.34)
Strength of Evidence | RCTs only | 4 | 0.22 (fair) (0.17 to 0.28) | 14.7% (6.8%) | r=−0.09 | 0.30 (fair) (0.17 to 0.43)

Abbreviations: AC1 = alternative chance-correlated coefficient = an alternative to a kappa statistic; CI = confidence interval; r = correlation; RCT = randomized controlled trial; SD = standard deviation.

Among individual reviewers and reviewer pairs, the level of agreement on the strength of evidence grade was fair for evaluations that solely included RCTs. By contrast, agreement was slight among individual reviewers and fair among reviewer pairs for evaluations that included both RCTs and observational studies.

We did not discern any patterns in the correlation between agreement among individual reviewers and the percentage of reviewers who found the rating difficult or very difficult. Agreement was greater among reconciled pairs of reviewers than it was among individual reviewers; the sole exception (very small) was for risk of bias for RCTs. We present greater detail on results specific to each of the domains and strength of evidence below.

## Risk of Bias

We had provided the reviewers with an assessment (rating) of the quality of each included study; for the two CERs used for this work, the authors had rated “quality” (rather than “risk of bias”) using longstanding formal practices. All RCTs included in the 10 exercises had been rated fair quality (Table 6).

Table 6 Summary of RCT risk of bias domain scores, by condition and outcome

Condition Outcome | Number of Studies (Total N of subjects) | Study Quality Ratings | Individual Domain Scores | Reconciled Domain Scores
MDD Benefits:; - HAM-D response | 5 (N=690) | All Fair | Low: 14% Medium: 86% High: 0% | Low: 18% Medium: 82% High: 0%
MDD Benefits:; - HAM-D & MADRS response in elderly | 1 (N=108) | Fair | Low: 5% Medium: 73% High: 23% | Low: 0% Medium: 73% High: 27%
MDD Harms:; - Sexual dysfunction | 4 (1 open label) (N=904) | All Fair | Low: 14% Medium: 82% High: 4% | Low: 9% Medium: 91% High: 0%
MDD Harms:; - Suicidality | 1 (N=90) | Fair | Low: 0% Medium: 82% High: 18% | Low: 0% Medium: 64% High: 36%
MDD Harms:; - Nausea | 5 (N=689) | All fair | Low: 14% Medium: 86% High: 0% | Low: 18% Medium: 82% High: 0%
RA Benefit:; - ACR20 | 5 (N=1,639) | All fair | Low: 14% Medium: 82% High: 4% | Low: 9% Medium: 91% High: 0%
RA Benefit:; - ACR70 | 5 (N=1,639) | All fair | Low: 9% Medium: 86% High: 5% | Low: 9% Medium: 91% High: 0%
RA Benefit:; - DAS remission | 2 (N=982) | All fair | Low: 9% Medium: 82% High: 9% | Low: 9% Medium: 82% High: 9%
RA Harms:; - Serious infection | 4 (N=1,215) | All fair | Low: 14% Medium: 82% High: 4% | Low: 18% Medium: 82% High: 0%
RA Harms:; - Infusion or injection reaction | 4 (N=1,108) | All fair | Low: 9% Medium: 91% High: 0% | Low: 9% Medium: 91% High: 0%

Abbreviations: ACR = American College of Rheumatology; DAS; Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MDD = major depressive disorder; N = number; RA = rheumatoid arthritis; RCT = randomized controlled trial.

Most observational studies had been rated fair quality; in two of the exercises, we included a single study that had been rated good quality (Table 7).

Table 7 Summary of observational study risk of bias domain scores, by condition and outcome

Condition Outcome | Number of Studies (Total N of subjects) | Study Quality Ratings | Individual Domain Scores | Reconciled Domain Scores
MDD Harms:; - Sexual dysfunction | 2 (N=3,154) | Both fair | Low: 14% Medium: 41% High: 45% | Low: 10% Medium: 45% High: 45%
MDD Harms:; - Suicidality | 2 (N=11,350) | 1 fair, 1 good | Low: 27% Medium: 41% High: 32% | Low: 18% Medium: 55% High: 30%
RA Benefits:; - ACR20 | 2 (N=2,461) | Both fair | Low: 4% Medium: 59% High: 36% | Low: 0% Medium: 64% High: 36%
RA Benefit:; - ACR70 | 1 (N=269) | Fair | Low: 5% Medium: 52% High: 43% | Low: 9% Medium: 55% High: 36%
RA Benefits:; - DAS remission | 1 (N=1,083) | Fair | Low: 18% Medium: 50% High: 32% | Low: 0% Medium: 73% High: 27%
RA Harms:; - Serious infection | 2 (N=7,695) | 1 fair, 1 good | Low: 18% Medium: 50% High: 32% | Low: 9% Medium: 64% High: 27%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; MDD = major depressive disorder; N = number; RA = rheumatoid arthritis.

A potential limitation of the risk of bias evaluation is that we did not give reviewers the specific criteria that had been used to develop the original individual quality ratings. Thus, they did not know the specific bias risks that would have caused a study to be rated as “fair” quality rather than “good.” Also, reviewers were not told whether limitations inherent in observational study design types had been incorporated into the quality rating that had been recorded for each of the observational studies. However, because two of the observational studies had been rated as “good” quality, our reviewers could have (reasonably) concluded that the original EPC authors were unlikely to have downgraded observational studies based on study design.

### Randomized Controlled Trials

In relation to the level of risk of bias of the RCTs included in the exercises, we found substantial agreement among both individuals (AC1=0.67) and pairs of raters (AC1=0.65) (Table 5). The study team had anticipated a high level of agreement among raters because all of the RCT studies had initially been rated fair quality.

With respect to comments from reviewers who found the evaluation of RCT risk of bias to be difficult, five of seven were concerned that the RA studies did not compare individual drugs. However, we had instructed reviewers to treat each of the drugs within a class as equivalent; thus, some unknown portion of the differences among reviewers’ risk of bias scores may be attributable to misinterpretation of these instructions.

In addition, two raters found evaluating risk of bias to be difficult when outcomes were not similarly specified across studies. This concern was expressed about the sexual dysfunction outcome for the MDD second-generation antidepressants study.

### Observational Studies

Across the six exercises that included observational studies, agreement among individual reviewers for risk of bias can be considered only slight (AC1=0.11). Agreement improved to fair (AC1=0.22) among pairs of reviewers for the reconciled responses. Even so, this level of agreement did not approach that for RCTs (Table 5).

Comments from those reviewers who thought that scoring risk of bias was difficult chiefly concerned a lack of confidence in the appropriate approach for evaluating this domain for observational studies. One reviewer thought that if just one observational study was being evaluated, then the risk of bias was high. This reviewer’s decision is in contrast to the EPC Methods Guide recommendation that the consistency domain score be used to capture the limitation of evidence from just one study.2 A second reviewer did not know how to evaluate an outcome, in this case sexual dysfunction, when it had been measured differently across studies. Similarly, this concern is discussed in guidance on rating the consistency domain. A third claimed that if included studies had different quality ratings, then the domain score should reflect the lowest contributing element. Finally, a fourth reviewer was not sure how to evaluate observational studies compared with RCTs; this individual did not know whether a high-quality observational study could be considered low risk of bias and chose never to consider such a study as better than medium risk.

## Consistency

### RCTs

Exercises evaluating MDD and RA outcomes based on RCT studies both included three outcomes with virtually all results in the same direction; two included only results that were not significantly different (Table 8). Two additional MDD outcomes were evaluated through just one study. Two additional RA outcomes included mixed results, including one study that did not report the magnitude of nonsignificant findings. The length of time over which outcomes had been evaluated varied across studies in these two CERs.

Table 8 Summary of RCT consistency domain scores, by condition and outcome

Condition Outcome | Number of Studies (Total N of subjects) | Direction of Difference Between Treatments and Significance | Individual Doman Scores | Reconciled Domain Scores
MDD Benefits:; - HAM-D response | 5 (N=690) | 4 of 5 studies: same direction; all studies: NS | Consistent: 91% Inconsistent: 9% Unknown: 0% | Consistent: 100% Inconsistent: 0% Unknown: 0%
MDD Benefits:; - HAM-D & MADRS response in elderly | 1 (N=108) | 1 study | Consistent: 5% Inconsistent: 0% Unknown: 95% | Consistent: 0% Inconsistent: 0% Unknown: 100%
MDD Harms:; - Sexual dysfunction | 4 (1 open label) (N=904) | All studies: same direction, different measures, some sig | Consistent: 14% Inconsistent: 36% Unknown: 23% | Consistent: 45% Inconsistent: 45% Unknown: 10%
MDD Harms:; - Suicidality | 1 (N=90) | 1 study | Consistent: 5% Inconsistent: 5% Unknown: 91% | Consistent: 0% Inconsistent: 0% Unknown: 100%
MDD Harms:; - Nausea | 5 (N=689) | 4 of 5 studies: same direction; all studies: NS | Consistent: 82% Inconsistent: 14% Unknown: 4% | Consistent: 91% Inconsistent: 9% Unknown: 0%
RA Benefit:; - ACR20 | 5 (N=1,639) | 4 of 5 studies: same direction; all studies: NS | Consistent: 10% Inconsistent: 86% Unknown: 4% | Consistent: 9% Inconsistent: 91% Unknown: 0%
RA Benefit:; - ACR70 | 5 (N=1,639) | 3 studies in same direction, 1 other direction, 1 data not reported, 4 studies: NS | Consistent: 48% Inconsistent: 48% Unknown: 4% | Consistent: 45% Inconsistent: 55% Unknown: 0%
RA Benefit:; - DAS remission | 2 (N=982) | Virtually all measures same direction, all studies: NS | Consistent: 82% Inconsistent: 4% Unknown: 14% | Consistent: 91% Inconsistent: 0% Unknown: 9%
RA Harms:; - Serious infection | 4 (N=1,215) | Mixed direction, all studies: NS | Consistent: 41% Inconsistent: 36% Unknown: 23% | Consistent: 91% Inconsistent: 9% Unknown: 0%
RA Harms:; - Infusion or injection reaction | 4 (N=1,108) | All same direction. 3 of 4 sig | Consistent: 82% Inconsistent: 14% Unknown: 4% | Consistent: 91% Inconsistent: 9% Unknown: 0%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MDD = major depressive disorder; N = number; NS = not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial; sig = statistically significant.

Scoring the consistency domain for RCTs across exercises produced moderate agreement among individuals (AC1=0.51); the level of agreement increased to substantial among pairs (AC1=0.70) (Table 5).

Independent reviewers were in poorest agreement in their consistency grade for serious infection from RA medications; 41 percent of the 22 individual reviewers found the studies consistent, 36 percent thought they were inconsistent, and 23 percent rated consistency as unknown (Table 8). Serious infections are a rare adverse event; moreover, study results had not always been in the same direction. Once the reviewer pairs had reconciled their scores, 91 percent of the pairs concluded that the results were consistent.

Reviewers who expressed difficulty in deciding on a grade were not confident about how to rate outcomes that included heterogeneous measures, even if the direction of the results had been the same. That is, they were unsure whether to consider them consistent or not applicable because just one study included each measure.

### Observational Studies

Exercises evaluating the consistency of outcomes based on observational studies were complicated. Three exercises had results in the same direction (two included indirect evidence—i.e., based on comparisons with a third reference drug); one had mixed results; and two included just one study (Table 9). Agreement was fair among individuals (AC1=0.40) and increased to moderate among pairs (AC1=0.55).

Table 9 Summary of observational study consistency domain scores, by condition and outcome

Condition Outcome | # of Studies (Total N) | Direction of Difference Between Treatments and Significance | Individual Domain Scores | Reconciled Domain Scores
MDD Harms:; - Sexual dysfunction | 2 (N=3,154) | Both studies: same direction, 1 indirect. 1 sig | Consistent: 50% Inconsistent: 18% Unknown: 32% | Consistent: 64% Inconsistent: 9% Unknown: 27%
MDD Harms:; - Suicidality | 2 (N=11,350) | Both studies: same direction, 1 indirect. Both: NS | Consistent: 59% Inconsistent: 18% Unknown: 23% | Consistent: 55% Inconsistent: 18% Unknown: 30%
RA Benefits:; - ACR20 | 2 (N=2,461) | Both studies: same direction. Both sig | Consistent: 73% Inconsistent: 14% Unknown: 14% | Consistent: 73% Inconsistent: 0% Unknown: 27%
RA Benefit:; - ACR70 | 1 (N=269 | 1 study | Consistent: 0% Inconsistent: 5% Unknown: 95% | Consistent: 0% Inconsistent: 0% Unknown: 100%
RA Benefits:; - DAS remission | 1 (N=1,083) | 1 study | Consistent: 0% Inconsistent: 9% Unknown: 91% | Consistent: 0% Inconsistent: 0% Unknown: 100%
RA Harms:; - Serious infection | 2 (N=7,695) | 1 study found difference (HR=1.39), 1 did not (RR=1) | Consistent: 23% Inconsistent: 68% Unknown: 9% | Consistent: 9% Inconsistent: 91% Unknown: 0%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; HR = hazard ratio; MDD = major depressive disorder; N = number; NS = not significant; RA = rheumatoid arthritis; RR = relative risk; sig = statistically significant

Agreement among reviewers was lowest for the outcomes of sexual dysfunction and suicidality. Both of these outcomes were evaluated through two studies with results in the same direction; however, for each outcome, evidence included one direct comparison and one indirect comparison.

Comments from reviewers indicated that they were concerned that they were unable to judge whether differences in treatments in the indirect comparisons were statistically significant and, therefore, whether the evidence was consistent.

## Directness

### RCTs

All RCT exercises were limited to direct head-to-head comparisons (Table 10). Generally, outcomes measured ultimate endpoints of interest. Agreement was substantial among individuals (AC1=0.73) and pairs (AC1=0.78) (Table 5). Suicidality is the one exception; data from the original CER had not included a study measuring the endpoint of suicide. Instead, reviewers were asked to consider one study that relied on measures of suicide attempts, ideation, and a scale score. Inter-rater reliability was poorest in relation to this outcome: 55 percent of individual reviewers considered the outcomes direct, whereas 45 percent considered them indirect.

Table 10 Summary of RCT directness domain scores, by condition and outcome

Condition Outcome | # of Studies (Total N) | Directness Summary | Individual Domain Scores | Reconciled Domain Scores
MDD Benefits:; - HAM-D response | 5 (N=690) | All head-to-head, outcome measured through 1 scale | Direct: 82% Indirect: 18% | Direct: 82% Indirect: 18%
MDD Benefits:; - HAM-D & MADRS response in elderly | 1 (N=108) | Head-to-head, outcome measured through 2 scales | Direct: 77% Indirect: 23% | Direct: 82% Indirect: 18%
MDD Harms:; - Sexual dysfunction | 4 (1 open label) (N=904) | Head-to-head, outcome measured through a variety of measures | Direct: 96% Indirect: 4% | Direct: 91% Indirect: 9%
MDD Harms:; - Suicidality | 1 (N=90) | Head-to-head, outcome measured through attempts, ideation and scale score | Direct: 55% Indirect: 45% | Direct: 45% Indirect: 55%
MDD Harms:; - Nausea | 5 (N=689) | All head-to-head | Direct: 100% Indirect: 0% | Direct: 100% Indirect: 0%
RA Benefit:; - ACR20 | 5 (N=1,639) | All head-to head, outcome measured through 1 scale | Direct: 86% Indirect: 14% | Direct: 100% Indirect: 0%
RA Benefit:; - ACR70 | 5 (N=1,639) | All head-to-head, outcome measured through 1 scale | Direct: 86% Indirect: 14% | Direct: 91% Indirect: 9%
RA Benefit:; - DAS remission | 2 (N=982) | Both head-to-head, outcome measured through 1 scale | Direct: 95% Indirect: 5% | Direct: 100% Indirect: 0%
RA Harms:; - Serious infection | 4 (N=1,215) | All head-to-head | Direct: 96% Indirect: 4% | Direct: 100% Indirect: 0%
RA Harms:; - Infusion or injection reaction | 4 (N=1,108) | All head-to-head | Direct: 91% Indirect: 9% | Direct: 91% Indirect: 9%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MDD = major depressive disorder; N = number; RA = rheumatoid arthritis; RCT = randomized controlled trial.

With respect to difficulty of this task, several reviewers expressed concern that they were not always confident of when to consider an outcome direct or indirect. One reviewer expressed confusion but concluded that all evidence with direct links to outcomes should be thought of as direct. A second thought that the meaning of directness was “arguable” but did not provide an explanation.

### Observational Studies

Observational study exercises included direct and indirect comparisons as well as variability in how included studies measured particular outcomes (Table 11). Agreement was moderate among individuals (AC1=0.48) and substantial among pairs (AC1=0.78) (Table 5). The higher level of agreement among pairs was related primarily to agreement increasing to 100 percent among pairs for the four RA outcomes, which were more clearly ultimate endpoints of interest. Agreement among pairs was less than 100 percent for MDD outcomes: sexual dysfunction (one direct comparison including various outcome measures and one indirect comparison) and suicidality (measured through nonfatal suicidal behavior, nonfatal self harm, and completed suicides).

Table 11 Summary of observational study directness domain scores, by condition and outcome

Condition Outcome | # of Studies (Total N) | Directness Summary | Individual Domain Scores | Reconciled Domain Scores
MDD Harms:; - Sexual dysfunction | 2 (N=3,154) | 1 head-to-head comparison, 1 indirect comparison, outcome measured through scales and specific symptoms | Direct: 64% Indirect: 36% | Direct: 64% Indirect: 36%
MDD Harms:; - Suicidality | 2 (N=11,350) | 1 head-to-head comparison, 1 indirect comparison, outcome measured through suicide and suicidal behaviors | Direct: 59% Indirect: 41% | Direct: 64% Indirect: 36%
RA Benefits:; - ACR20 | 2 (N=2,461) | Both head-to-head comparisons, outcome measured through 1 scale | Direct: 82% Indirect: 18% | Direct: 100% Indirect: 0%
RA Benefit:; - ACR70 | 1 (N=269) | 1 head-to-head, outcome measured through 1 scale | Direct: 81% Indirect: 19% | Direct: 100% Indirect: 0%
RA Benefits:; - DAS remission | 1 (N=1,083) | 1 head-to-head, outcome measured through 1 scale | Direct: 86% Indirect: 14% | Direct: 100% Indirect: 0%
RA Harms:; - Serious infection | 2 (N=7,695) | Both head-to-head | Direct: 91% Indirect: 9% | Direct: 100% Indirect: 0%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; MDD = major depressive disorder; N = number; RA = rheumatoid arthritis.

In relation to these two outcomes, reviewers who expressed difficulty were unsure of what to do when the evidence is mixed. That is, the evidence base might include studies with direct and indirect comparisons, or it might include studies with ultimate and intermediate measures of outcomes or heterogeneous outcome measures (and, of course, it might have all of these complications).

## Precision

### RCTs

In relation to outcomes evaluated through RCTs, only one of the 10 exercises provided reviewers with an estimate of precision based on the results from a meta-analysis (Table 12). Two exercises were limited to one study. In both, although differences between drugs for MDD were said to be statistically significant, the authors of the original studies had not presented confidence intervals, and only one article had included outcome rates for both arms of the study. Three exercises included studies of differences that were all not statistically significant, and four included results that were mixed. Inter-rater reliability agreement based on RCT evidence was lowest for this domain: fair among individual raters (AC1=0.23) but moderate (AC1=0.47) after results were reconciled among pairs (Table 5).

Table 12 Summary of RCT precision domain scores, by condition and outcome

Condition Outcome | # of Studies (Total N) | Difference Between Treatments | Individual Domain Scores | Reconciled Domain Scores
MDD Benefits:; - HAM-D response | 5 (N=690) | Meta-analysis result: 1.03; 95% CI, 0.92 to 1.16 | Precise: 82% Imprecise: 18% | Precise: 82% Imprecise: 18%
MDD Benefits:; - HAM-D & MADRS response in elderly | 1 (N=108) | 2 measures, p-value for both: <0.05, rates and CI not provided | Precise: 50% Imprecise: 50% | Precise: 55% Imprecise: 45%
MDD Harms:; - Sexual dysfunction | 4 (1 open label) (N=904) | Various measures, 1: p<0.05, all others: p=NS; rates provided in 3 of 4 but no CI | Precise: 18% Imprecise: 82% | Precise: 0% Imprecise: 100%
MDD Harms:; - Suicidality | 1 (N=90) | p=0.026, rate provided, but no CIs | Precise: 18% Imprecise: 82% | Precise: 18% Imprecise: 82%
MDD Harms:; - Nausea | 5 (N=689) | All studies NS; 4 of 5: rate provided but no CIs | Precise: 45% Imprecise: 55% | Precise: 45% Imprecise: 55%
RA Benefit:; - ACR20 | 5 (N=1,639) | Mix of endpoints: 3 of 5: p<0.05; at 12 months: 2 of 3: p=NS, rates provided, but no CIs | Precise: 18% Imprecise: 82% | Precise: 0% Imprecise: 100%
RA Benefit:; - ACR70 | 5 (N=1,639) | 4 of 5: p=NS; 3 of 4: rates provided, but no CIs | Precise: 19% Imprecise: 81% | Precise: 0% Imprecise: 100%
RA Benefit:; - DAS remission | 2 (N=982) | All outcomes: p=NS; rates for each treatment close, but no CIs | Precise: 45% Imprecise: 55% | Precise: 64% Imprecise: 36%
RA Harms:; - Serious infection | 4 (N=1,215) | All: NS, no CIs | Precise: 18% Imprecise: 82% | Precise: 36% Imprecise: 64%
RA Harms:; - Infusion or injection reaction | 4 (N=1,108) | 3 of 4: p<0.05, rates provided, but no CIs | Precise: 77% Imprecise: 23% | Precise: 100% Imprecise: 0%

Abbreviations: ACR = American College of Rheumatology; CI = confidence interval; DAS = Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MDD = major depressive disorder; N = number; NR = not reported; NS = not significant; RA = rheumatoid arthritis; RCT = randomized controlled trial.

Reviewers expressed difficulty in evaluating this domain for the exercises that did not include meta-analyses; they thought that more guidance was needed for that circumstance. Some were concerned that they did not know the level of precision that was required to evaluate an estimate as being precise. In particular, even if an estimate had reported a statistically significant difference between drugs or drug classes, some reviewers expressed difficulty in making determinations without having confidence intervals to evaluate. One reviewer thought that the guidance alluded to the notion that nonsignificant differences could be precise under some circumstances but did not know how to make that determination. Also, reviewers raised questions about how to approach scoring precision when an outcome was evaluated through different measures; they were unsure of whether they should consider the measures in combination or evaluate them separately. Lastly, some reviewers found the scoring difficult when the outcome was assessed through one study and wondered whether the domain should be considered inapplicable in those cases.

### Observational Studies

Agreement among raters on their evaluation of the precision of observational studies was fair for individuals (AC1=0.31) and for pairs (AC1=0.38) (Table 5). Several examples of exercises with poor agreement are instructive. In the exercise evaluating sexual dysfunction, 36 percent of individual reviewers thought the evidence was precise, whereas 64 percent thought it was imprecise (Table 13). This outcome was evaluated through two different measures—a direct comparison with significant results but no confidence intervals presented and an indirect comparison with overlapping confidence intervals for each of the two drugs being compared and a third drug (Table 13). In the exercise evaluating ACR20, 59 percent of independent reviewers through the evidence was precise whereas 41 percent thought it was imprecise. This exercise included statistically significant findings from two studies; the first presented p-values but no point estimates for differences between the drug classes, and the second presented confidence intervals in an adjusted analysis.

Table 13 Summary of observational study precision domain scores, by condition and outcome

Condition Outcome | # of Studies (Total N) | Difference Between Treatments | Individual Domain Scores | Reconciled Domain Scores
MDD Harms:; - Sexual dysfunction | 2 (N=3,154) | 1 direct comparison, multiple measures, all sig and in same direction, no CIs; 1 indirect comparison, NS, overlapping CIs | Precise: 36% Imprecise: 64% | Precise: 45% Imprecise: 55%
MDD Harms:; - Suicidality | 2 (N=11,350) | 1 indirect comparison: NS, overlapping CIs 1 direct nested case-control adjusted comparison: 2 measures, both NS, CIs reported | Precise: 32% Imprecise: 68% | Precise: 27% Imprecise: 73%
RA Benefits:; - ACR20 | 2 (N=2,461) | 1 study: sig difference, no data, p-values only, 1 adjusted study: sig diff, CI reported | Precise: 59% Imprecise: 41% | Precise: 45% Imprecise: 55%
RA Benefit:; - ACR70 | 1 (N=269) | Difference reported through p-value only, NS, no results data | Precise: 5% Imprecise: 95% | Precise: 0% Imprecise: 100%
RA Benefits:; - DAS remission | 1 (N=1,083) | Adjusted analysis: sig, CIs presented, matched pairs analysis: sig, CIs not reported | Precise: 55% Imprecise: 45% | Precise: 82% Imprecise: 18%
RA Harms:; - Serious infection | 2 (N=7,695) | Adjusted analyses in each study, 1 sig, 1 NS, CIs presented for both | Precise: 14% Imprecise: 86% | Precise: 36% Imprecise: 64%

Abbreviations: ACR = American College of Rheumatology; CI = confidence interval; DAS = Disease Activity Scale; MDD = major depressive disorder; N = number; NS = not significant; RA = rheumatoid arthritis; sig = statistically significant.

Comments from raters concerning the difficulty of evaluating the precision of observational studies were similar to those for RCTs.

## Strength of Evidence

Inter-rater reliability agreement was slight among individual reviewers (AC1=0.20) but improved to fair (AC1=0.24) after results were reconciled among pairs (Table 5). On average, almost 20 percent of reviewers reported that the exercise of grading the overall strength of evidence was difficult or very difficult.

We considered whether reviewers’ agreement on the strength of evidence grade was greater when they completed exercises that included only RCTs (four exercises) than when they completed exercises that included both RCTs and observational studies (all 10 exercises). Inter-rater reliability did not improve appreciably; agreement was fair among individual reviewers (AC1=0.22) and reconciled pairs (AC1=0.30) for the four exercises that include only RCTs.

Table 14 presents the grading results for each exercise. Even after grades were reconciled with partners, many results varied widely. At the extreme, reconciled grades for the MDD harm of nausea included all four possibilities (high, moderate, low, and insufficient), as did the RA benefit of ACR70 scores and the RA harm of severe infection.

Table 14 Strength of evidence grades, by condition and outcome

Condition Outcome | Individual SOE Grades | Reconciled SOE Grades
MDD Benefits:; - HAM-D response | High: 23% Moderate: 64% Low: 14% Insufficient: 0% | High: 18% Moderate: 73% Low: 9% Insufficient: 0%
MDD Benefits:; - HAM-D & MADRS response in elderly | High: 0% Moderate: 5% Low: 45% Insufficient: 50% | High: 0% Moderate: 0% Low: 45% Insufficient: 55%
MDD Harms:; - Sexual dysfunction | High: 0% Moderate: 18% Low: 64% Insufficient: 18% | High: 0% Moderate: 9% Low: 82% Insufficient: 9%
MDD Harms:; - Suicidality | High: 5% Moderate: 18% Low: 36% Insufficient: 41% | High: 0% Moderate: 9% Low: 45% Insufficient: 45%
MDD Harms:; - Nausea | High: 19% Moderate: 62% Low: 10% Insufficient: 10% | High: 18% Moderate: 55% Low: 9% Insufficient: 18%
RA Benefit:; - ACR20 | High: 0% Moderate: 18% Low: 59% Insufficient: 23% | High: 0% Moderate: 18% Low: 55% Insufficient: 27%
RA Benefit:; - ACR70 | High: 5% Moderate: 19% Low: 62% Insufficient: 14% | High: 9% Moderate: 18% Low: 55% Insufficient: 18%
RA Benefit:; - DAS remission | High: 0% Moderate: 19% Low: 52% Insufficient: 29% | High: 0% Moderate: 9% Low: 55% Insufficient: 36%
RA Harms:; - Serious infection | High: 9% Moderate: 18% Low: 45% Insufficient: 27% | High: 9% Moderate: 27% Low: 45% Insufficient: 18%
RA Harms:; - Infusion or injection reaction | High: 27% Moderate: 55% Low: 18% Insufficient: 0% | High: 18% Moderate: 73% Low: 9% Insufficient: 0%

Abbreviations: ACR = American College of Rheumatology; DAS = Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; MDD = major depressive disorder; RA = rheumatoid arthritis; SOE = strength of evidence.

We explored patterns among reviewer pairs in the relationship between domain scores and strength of evidence grades for two exercises with very divergent conclusions. Table 15 presents reconciled domain scores and strength of evidence grades for each reviewer pair from the exercises on MDD harm of nausea (five studies, all RCTs) and the RA benefit of ACR70 (six studies, five of which were RCTs).

Table 15 Detail of reconciled pair assessments for two exercises with poor agreement across pairs: antidepressant harms (nausea)^a^ and rheumatoid arthritis benefit (ACR70)

Reviewer Pair^b^ | Risk of Bias^c^ | | Consistency^d^ | | Directness^e^ | | Precision^f^ | | Strength of Evidence^g^
| RCTs | Obs | RCTs | Obs | RCTs | Obs | RCTs | Obs
Nausea 1. | Low | | Consistent | | Direct | | Imprecise | | High
Nausea 2. | Low | | Consistent | | Direct | | Precise | | High
Nausea 3. | Medium | | Consistent | | Direct | | Precise | | Moderate
Nausea 4. | Medium | | Consistent | | Direct | | Imprecise | | Moderate
Nausea 5. | Medium | | Consistent | | Direct | | Precise | | Moderate
Nausea 6. | Medium | | Consistent | | Direct | | Imprecise | | Moderate
Nausea 7. | Medium | | Consistent | | Direct | | Imprecise | | Moderate
Nausea 8. | Medium | | Consistent | | Direct | | Precise | | Moderate
Nausea 9. | Medium | | Consistent | | Direct | | Imprecise | | Low
Nausea 10. | Medium | | Consistent | | Direct | | Imprecise | | Insufficient
Nausea 11. | Medium | | Inconsistent | | Direct | | Imprecise | | Insufficient
ACR70 1. | Low | High | Inconsistent | NA | Direct | Direct | Imprecise | Imprecise | High
ACR70 2. | Medium | Medium | Consistent | NA | Direct | Direct | Imprecise | Imprecise | Moderate
ACR70 3. | Medium | Medium | Inconsistent | NA | Indirect | Direct | Imprecise | Imprecise | Moderate
ACR70 4. | Medium | High | Inconsistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 5. | Medium | Medium | Inconsistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 6. | Medium | High | Inconsistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 7. | Medium | Medium | Inconsistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 8. | Medium | High | Consistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 9. | Medium | Medium | Consistent | NA | Direct | Direct | Imprecise | Imprecise | Low
ACR70 10 | Medium | Low | Consistent | NA | Direct | Direct | Imprecise | Imprecise | Insufficient
ACR70 11. | Medium | Medium | Consistent | NA | Direct | Direct | Imprecise | Imprecise | Insufficient

a This exercise included only RCTs.

b The number assigned to each review pair is arbitrary and does not represent the same pair for the nausea and ACR70 evaluations.

c Risk of bias scoring choices were low, medium or high

d Consistency scoring choices were consistent, inconsistent, or unknown (NA)

e Directness scoring choices were direct or indirect

f Precision scoring choices were precise and imprecise

g Strength of evidence grading choices were high, medium, low, or insufficient

Abbreviations: ACR =, American College of Rheumatology; NA = consistency score not applicable (single study); Obs = observational studies; RCTs = randomized controlled trials.

The antidepressant harm outcome of nausea evaluation consisted of all fair-quality RCTs; each had a relatively small sample size. In four of the studies, a larger percentage of patients experienced nausea in the paroxetine arm but none of the differences were statistically significant (presented only through p-values). Only the two pairs that scored RCT risk of bias as low concluded that the strength of evidence was high. Five of the 11 pairs of reviewers had all of the same domain score assessments but they differed in their strength of evidence grade; moderate (three pairs), low (one pair), or insufficient (one pair). This was likely related to different views of the appropriate strength of the evidence grade when the evidence is imprecise; other scores among these pairs were medium risk of bias, consistent and direct. Three other of the 11 pairs, evaluated the evidence as medium risk of bias, consistent, direct but precise, and all of these pairs graded the strength of evidence as moderate.

The ACR70 evaluation is a good example of the complexity of the decision faced by reviewers in an evaluation that included both RCTs and observational studies. In this exercise, four of five trials and the one included large observational study did not find significant differences between treatments. One of the RCTs and the observational study did not report the percentage of patients in each arm who achieved the outcome. All studies were considered fair quality and outcomes were evaluated after different lengths of time. Statistical significance was presented only through p-values.

As was found in the nausea exercise, a conclusion of high strength of evidence was made only when RCT risk of bias was assessed as low. Patterns of differences in ACR70 strength of evidence grading were not explained by domain scores. For example, 3 of the 11 pairs had all of the same domain score assessments but reached different strength of evidence grades (moderate, low, and insufficient).

Comments from reviewers indicated that higher grades were associated with confidence in a conclusion that the evidence in this exercise summed to no difference in effect. Although distinguishing the reasons behind grades of low versus insufficient is difficult, both of these groups of reviewers (the majority of participants) seemed more reluctant to give a higher grade to findings that appeared to show no difference.

### Predictions of Strength of Evidence Grades From Domain Scores

We used two multinomial logistic regression analyses to examine the relationship between independent reviewers’ strength of evidence grades and domain scores (Table 16). Based on results from the six exercises that included RCTs and observational studies (Model 1), reviewers who considered the evidence from observational studies as being low risk of bias (vs. high) were more than 500 percent more likely (i.e., OR=6.77) to grade strength of evidence as insufficient (vs. moderate or high). Reviewers who considered the evidence from observational studies as being consistent (vs. unknown consistency) were 86 percent less likely (i.e., OR=0.14) to grade strength of evidence as insufficient (vs. moderate or high). By contrast, reviewers who considered the evidence from RCTs as being precise (vs. imprecise) were 75 percent less likely (i.e., OR=0.25) to grade strength of evidence as low (vs. moderate or high).

Table 16 Prediction of strength of evidence grade by domain scores: odds ratio from multinomial logistic regression results

Domain/Strength of Evidence | Study Design | Domain Score | Strength of Evidence Model 1 | | Strength of Evidence Model 2
Domain/Strength of Evidence | Study Design | Domain Score | vs. Moderate or High | | vs. Moderate or High
Domain/Strength of Evidence | Study Design | Domain Score | Insufficient | Low | Insufficient | Low
Risk of bias (vs. high) | RCT | Medium | 9.70 | 3.41 | 2.52 | 2.78
Risk of bias (vs. high) | RCT | Low | 1.00 | 0.55 | 0.34 | 0.60
Risk of bias (vs. high) | Observational | Medium | 1.76 | 1.13 | NA | NA
Risk of bias (vs. high) | Observational | Low | 6.77^a^ | 1.69 | NA | NA
Consistency (vs. unknown or NA) | RCT | Consistent | 0.18 | 1.33 | 0.04^a^ | 0.12^a^
Consistency (vs. unknown or NA) | RCT | Inconsistent | 0.90 | 3.14 | 0.18^a^ | 0.36
Consistency (vs. unknown or NA) | Observational | Consistent | 0.14^a^ | 0.32 | NA | NA
Consistency (vs. unknown or NA) | Observational | Inconsistent | 1.99 | 0.77 | NA | NA
Directness (vs. indirect) | RCT | Direct | 0.89 | 0.45 | 0.93 | 0.65
Directness (vs. indirect) | Observational | Direct | 0.79 | 0.55 | NA | NA
Precision (vs. imprecise) | RCT | Precise | 0.19 | 0.25^a^ | 0.25^a^ | 0.39^a^
Precision (vs. imprecise) | Observational | Precise | 0.26 | 0.56 | NA | NA
| With observational studies in exercise (vs. only RCT studies included in exercise) | | NA | NA | 4.10^a^ | 6.02^a^

a p<0.05

Abbreviations: NA = not applicable; RCT = randomized controlled trials.

Based on results from all 10 exercises (Model 2 in Table 16), the reviewers were more likely to grade strength of evidence as insufficient or low (vs. moderate or high) if the exercise included observational studies, controlling for RCT domain scores. Also, reviewers’ strength of evidence grades were significantly less likely to be insufficient if results from RCT evidence were considered either consistent or inconsistent (vs. unknown consistency) or precise (vs. imprecise). They were less likely to grade strength of evidence as low (vs. moderate or high) if the evidence from RCTs were considered consistent (vs. unknown consistency) or precise (vs. imprecise).

### Predictions of Level of Agreement in Strength of Evidence Grades From Level of Agreement in Domain Scores

We estimated two logistic regression equations (Models 3 [with observational studies] and 4 [only RCTs]) to examine the association between independent reviewers’ agreement on domain scores and their eventual agreement on strength of evidence grade (Table 17). Across all analyses, we did not find that agreement on any of the domain scores predicted agreement on the strength of evidence grade. Taking precision scores for observational studies as one example (in Model 3), reviewers who agreed (relative to not agreeing on the score) were 87 percent more likely (OR=1.87) of agreeing on the strength of evidence grade, but this result was not statistically significant. Looking at only agreement on RCT evidence (in Model 4), reviewers who agreed on RCT risk of bias (relative to not agreeing on the score) were 51 percent more likely (OR=1.51) of agreeing on the strength of evidence grade, but again, this result was not statistically significant.

Table 17 Prediction of agreement on strength of evidence grade by agreement on domain scores: Odds ratios from logistic regression results

Domain | Study Design | Agree Strength of Evidence (vs. not) Model 3 | Agree Strength of Evidence (vs. not) Model 4
Risk of bias | RCT | 1.56 | 1.51
Risk of bias | Observational | 0.68 | NA
Consistency | RCT | 1.26 | 1.71
Consistency | Observational | 0.91 | NA
Directness | RCT | 0.84 | 0.76
Directness | Observational | 1.02 | NA
Precision | RCT | 1.36 | 1.44
Precision | Observational | 1.87 | NA
| No observational studies in exercise | NA | 1.00

No results were statistically significant (p<0.05)

Abbreviations: NA = not applicable; RCT = randomized controlled trials.

## Subgroup Analyses of Independent Reviewer Assessments

We reviewed independent reviewer agreement in domain scores and strength of evidence grades by condition (i.e., MDD or RA), type of outcome (i.e., benefit or harm), reviewer academic training (i.e., physician or nonphysician), and years of experience in conducting systematic or comparative effectiveness reviews and evaluating strength of evidence. Across all subgroups, agreement on the strength of evidence grade was lower than for virtually all domain-specific scores.

With respect to condition (Table 18), reviewers’ agreement on seven of eight domain scores was greater (shown in bold) for RA than MDD. Two differences between MDD and RA (consistency and directness for observational studies) were statistically significant. However, agreement in RA domain scoring did not correspond to greater agreement for the RA strength of evidence grade; the level of agreement was nearly identical.

Table 18 Percentage agreement among independent reviewers, by condition (MDD vs. RA) and outcome (benefits vs. harms)

Domain/Strength of Evidence | Study Design | MDD | RA | Benefits | Harms
Risk of Bias | RCTs | 82% | 86% | 82% | 86%
Risk of Bias | Observational | 43% | 53% | 54% | 45%
Consistency | RCTs | 80% | 73% | 80% | 73%
Consistency | Observational | 55%^*^ | 82% * | 86% * | 59%^*^
Directness | RCTs | 82% | 92% | 85% | 88%
Directness | Observational | 62%^*^ | 85% * | 83% | 71%
Precision | RCTs | 70% | 72% | 70% | 72%
Precision | Observational | 66% | 74% | 70% | 73%
Strength of Evidence | | 56% | 54% | 58% | 52%

* p<0.05, based on individual-level data and controlling for repeated measures. (N = 22)

Note: bolded score denotes greater agreement across reviewers.

Abbreviations: MDD = major depressive disorder; RA = rheumatoid arthritis; RCT = randomized controlled trials.

By type of outcome (Table 18), half of the eight comparisons showed greater agreement for benefits; only agreement about consistency for observational studies was significantly different between benefits and harms. Reviewers agreed 58 percent of the time on strength of evidence grades for exercises examining benefits and 52 percent of the time for exercises examining harms.

Of 22 reviewers, eight were physicians by academic training; the remainder represented a range of social science and methodologic backgrounds (Table 19). Of the eight comparisons of agreement on domain scores, six showed greater agreement among those reviewers with professional backgrounds other than medicine. However, the one significant result—agreement on scoring risk of bias for RCTs—showed greater agreement among physician than nonphysician reviewers. Like the analysis by condition, greater agreement across domain scoring among nonphysicians did not correspond with greater agreement in strength of evidence grading (58 percent of physicians and 53 percent of nonphysicians).

Table 19 Percentage agreement among independent reviewers, by reviewer academic training, experience in conducting systematic or comparative effectiveness reviews, and experience evaluating strength of evidence

Domain/Strength of Evidence | Study Design | Physician Academic Training | Non-Physician Academic Training | >= 10 Reviews | <10 Reviews | >=5 Evaluations of SOE | <5 Evaluations of SOE
Risk of Bias | RCTs | 96% * | 77%^*^ | 88% | 79% | 80% | 86%
| Observational | 79% | 76% | 56% | 41% | 45% | 52%
Consistency | RCTs | 84% | 88% | 78% | 74% | 70% | 80%
| Observational | 68% | 72% | 70% | 76% | 62% | 78%
Directness | RCTs | 42% | 54% | 88% | 84% | 90% | 85%
| Observational | 71% | 73% | 82% | 70% | 79% | 76%
Precision | RCTs | 69% | 82% | 69% | 72% | 73% | 69%
| Observational | 65% | 75% | 77% * | 63%^*^ | 79% | 67%
Strength of Evidence | | 58% | 53% | 50% | 61% | 46% | 59%

* p<0.05, based on individual-level data and controlling for repeated measures. (Reviewer academic training: N = 22; Number of reviews and number of times evaluating strength of evidence: N = 21)

Note: bolded score denotes greater agreement across reviewers.

Abbreviations: RCT = randomized controlled trials; SOE = strength of evidence.

Reviewer experience conducting reviews and evaluating strength of evidence was available for 21 reviewers. Experience conducting reviews ranged from two reviews (two reviewers) to 25 or more reviews (five reviewers); 10 reviewers had conducted 10 or more reviews. More experienced reviewers showed greater agreement for six of eight domain scores (only scoring of precision of observational studies was statistically significant). Greater agreement across domain scoring among more experienced reviewers corresponded with poorer agreement in strength of evidence grading (50 percent of more experienced reviewers and 61 percent of less experienced reviewers.)

Reviewer experience evaluating strength of evidence ranged from none (two reviewers) to 10 or more times (four reviewers); seven reviewers had evaluated strength of evidence five or more times. Reviews with greater experience in evaluating strength of evidence showed greater agreement across half of the eight domain scores (none of the differences were statistically significant). Like the analysis of experience in conducting reviews, greater experience in evaluating strength of evidence corresponded with poorer agreement in strength of evidence grading (46 percent of more experienced graders and 59 percent of less experienced graders).

## Reconciliation Across Reviewer Pairs

We received responses from 8 of the 11 pairs describing the approach each of the reviewers had used independently to assign overall strength of evidence grades. They generally described their approach as qualitative, reflecting the lack of meta-analytic results data in 9 of the 10 exercises that would have lent themselves to quantitative analyses. The methods approach for qualitative assessment differed across reviewers. Two pairs included independent reviewers who used a different approach: in one pair, one reviewer used the EPC’s own approach of assessing the direction and size of effect separately, while the other followed guidance in Owens et al.2; in the second, one reviewer used the GRADE approach and the second used the guidance in Owens et al.2 Other pairs of reviewers used the same approach as each other.

The approaches were described as in various ways: a subjective judgment based on a mix of quantitative and qualitative analyses; a qualitative approach based on guidance in Owens et al.;2 the EPC’s own approach; the EPCs own qualitative approach guided by GRADE, Owens et al.,2 and US Preventive Services Task Force guidance; an approach based on Owens et al.2 with rules for assigning particular grades, such as high strength of evidence limited to outcomes with “perfect” domain scores (i.e., low risk of bias, consistent, direct, and precise); and lastly, the EPC’s own approach first and then consideration of guidance in Owens et al.2 We did not conduct subgroup analyses based on the approach used to assign grades because we lacked sufficient data to sort approaches into meaningful categories.

Only one pair of reviewers used a third party to adjudicate differences in their domain scores or strength of evidence grades. We did not conduct subgroup analyses based on this distinction because with only one EPC using adjudication, we would have been unable to conclude that any differences in results were based on the pair’s adjudication per se or other unmeasured characteristics of the reviewer pair.

The majority of individually determined domain scores were the same for both partners; i.e., these scores did not change during the reconciliation process (Table 20). Taking risk of bias as the example, summing across all 10 outcomes, pairs agreed on 82 percent of the RCT risk of bias scores (top row of Table 20); of the remaining scores, they reconciled 9 percent of their scores to be better (lower risk of bias) and 9 percent to be worse (higher risk of bias) than either or both of their individual scores. By contrast, for observational studies precision, they agreed on 67 percent of domain scores and reconciled 18 percent and 15 percent, respectively, to be better (precise) or worse (imprecise) in contrast to either or both of their individual scores.

Table 20 Mean percentage change in domain scores and the strength of evidence grade following reconciliation

Domain/Strength of Evidence | Study Design | Agree (No change) | Better (Higher score) | Worse (Lower score)
Risk of bias | RCT | 82% | 9% | 9%
Risk of bias | Observational | 50% | 24% | 26%
Consistency | RCT | 69% | 21% | 10%
Consistency | Observational | 77% | 11% | 12%
Directness | RCT | 82% | 11% | 7%
Directness | Observational | 65% | 27% | 8%
Precision | RCT | 67% | 15% | 18%
Precision | Observational | 67% | 18% | 15%
Strength of Evidence | Overall combined | 46% | 25% | 30%

Results for domain scores for RCT studies and strength of evidence are based on 11 pairs evaluating 10 outcomes (N = 110).

Results for domain scores on observational studies are based on 11 pairs evaluating 6 outcomes (N = 66).

Abbreviations: RCT = randomized controlled trial.

Agreement for domain scores ranged from a low of 50 percent to a high of 82 percent. For changes in scores that needed to be reconciled, we found no consistent pattern toward either better or worse scores. One exception may be of interest: the reconciled scores for directness for RCTs and observational studies were both in the direction of “better” scores (going from indirect to direct).

Initial agreement across pairs of reviewers—46 percent—was poorer for overall strength of evidence grades than it was for any of the domain scores. Of the remaining overall grades, about half were reconciled to be better (25 percent) and the remainder were reconciled worse (30 percent).

The pattern of reconciliation to better or worse overall strength of evidence grades was not generally related to the grades that were being reconciled. For example, among the 22 assessments where one reviewer in the pair originally assessed the grade as low and the other reviewer assessed the grade as insufficient, 11 were reconciled to low and 11 were reconciled to insufficient (data not shown). Similarly, among the 11 assessments where one reviewer in the pair originally assessed the grade as high and the other reviewer assessed the grade as moderate, five were reconciled to high, five to moderate, and one to low (data not shown). In contrast, among the seven assessments where one reviewer in the pair originally assessed the grade as moderate and the other reviewer assessed the grade as insufficient, five were reconciled to insufficient (data not shown).