# Methods

## Information From Recent Comparative Effectiveness Reviews

We conducted the inter-rater reliability testing using data from two published CERs focusing on two distinct chronic conditions and drug treatments: second-generation antidepressants for the treatment of major depressive disorder (MDD) and disease-modifying antirheumatic drugs (DMARDs) for the treatment of rheumatoid arthritis (RA).6,7 From the data in these reviews, the study team designed 10 exercises, which are summarized in Table 3. All 10 exercises included RCTs, and 6 of the 10 also included one or more observational studies. Using the same terminology as is used in the AHRQ Methods Guide chapter on strength of evidence grading, observational studies include nonrandomized trials, cohort, cross-sectional, and case-control studies. The risk of bias of individual studies was provided as a quality score (good, fair, or poor) because this was the metric used by the original reviewers. These exercises together evaluated a variety of efficacy (benefit) and adverse event (harm) outcomes across the two conditions.

Table 3 Grading exercises: description and main characteristics of evidence

Condition Outcome | RCTs Number of Studies^a^ (Total N across studies) | Observational Studies Number of Studies (Total N across studies) | Main Characteristics and Challenges of the Exercise
MDD Benefits:; - HAM-D response | 5 studies8–12 (N=690) | None | All RCTs with similar results Evaluation of pooled data (meta-analysis results) Exercise considered straightforward by study team
MDD Benefits:; - Efficacy response in subpopulation of elderly | 1 study13 (N=108) | None | Limited to one RCT evaluated through 2 outcome measures Results in bar graph only (no exact scores) Precision presented through p-values only (no confidence intervals) Exercise considered straightforward by study team
MDD Harms:; - Sexual dysfunction | 4 studies8,10,11,14 (N=904 | 2 studies15,16 (1 prospective cohort, 1 large cross-sectional survey) (N=3,154) | Mix of study designs: 4 RCTs (including 1 open-label), 2 observational studies Outcome measure differed across studies Indirect measure in cross-sectional study Exercise considered challenging by study team
MDD Harms:; - Suicidality | 1 study12 (N=90) | 2 studies17,18 (1 case-control and 1 large good-quality nested case- control) (N=11,350) | Mix of study designs: 1 RCT, 2 observational studies Only RCT found difference Outcome measures differed across studies, some measure ideation Exercise considered challenging by study team
MDD Harms:; - Nausea | 5 studies8,9,11–13 (N=689) | None | All RCTs No significant differences between arms in any study. In 4 studies, paroxetine has higher rates and in 1 study fluoxetine has a higher rate. Exercise considered straightforward by study team
RA Benefits:; - ACR20 response | 5 studies19–27 (N=1,639) | 2 studies28,29 (1 nonrandomized trial, 1 prospective cohort ) (N=2,461) | Mix of study designs: 5 RCTs, 2 observational studies Different followup durations Mixed results Composite outcome in 1 study Exercise considered challenging by study team
RA Benefits:; - ACR70 response | 5 studies19–27 (N=1,639) | 1 study28 (nonrandomized open-label trial) (N=269) | 5 RCTs, 1 observational study Only 1 study found a difference between treatments Different followup durations Same included studies as ACR20 exercise plus the addition of an observational study Exercise considered challenging by the study team
RA Benefits:; - DAS remission | 2 studies20,23,25–27 (N=982) | 1 study30 (prospective cohort) (N=1,083) | Mix of study designs; 2 RCTs did not find a difference, but 1 large observational study did. Exercise considered challenging by study team
RA Harms:; - Serious infection | 4 studies20–23,25–27 (N=1,215) | 2 studies31,32 (1 large fair retrospective cohort and 1 good retrospective cohort) (N=7,695) | Mix of study designs: 4 fair RCTs, 2 observational studies Difference found in only 1 large retrospective study Outcome is rare, so few events Exercise requires incorporating retrospective data Exercise considered challenging by study team
RA Harms:; - Infusion or injection reaction | 4 studies19,21–27 (N=1,108) | None | All RCTs Differences seen in 3 of 4 studies; no difference found in the smallest study Exercise considered straightforward by study team

a Numbers of citations may exceed number of studies when the latter are published in multiple articles.

Abbreviations: ACR = American College of Rheumatology; CI = confidence interval; DAS = Disease Activity Scale; HAM-D = Hamilton Rating Scale for Depression; MDD = major depressive disorder; N = number; RA = rheumatoid arthritis; RCT = randomized controlled trial.

The exercises also provided a range of intellectual challenges relating to evaluating different aspects of the strength of evidence guidance (see right column of Table 3). These challenges included:

- data that did not lend themselves to meta-analysis; only one exercise (response on the Hamilton Rating Scale for Depression [HAM-D]) evaluated pooled data through results from a meta-analysis of RCTs;
- outcomes evaluated with different measures across studies;
- inconsistent lengths of time across studies for when outcomes were measured;
- outcomes evaluated through both RCTs and observational studies;
- limited information in studies, such as the inclusion of p-values but no confidence intervals;
- differences in sample sizes across studies; and
- differences in study quality (risk of bias).

The project was not a perfect replica of the actual data confronted and processes undertaken by EPC investigators in grading the strength of a body of evidence in a CER or systematic review. Instead, we attempted to replicate the key parts of the process as closely as possible, acknowledging time constraints of the reviewers. Our goal was to craft a dataset that addressed a wide range of factors in grading strength of evidence but that did not require either prior knowledge of the subject matter or an unreasonable amount of time to complete the exercises in a thoughtful and meaningful way. Thus, we did not replicate the analysis conducted through the original CERs; this project should not be considered a reevaluation of the results presented in the original reports.

For MDD, we focused solely on treatment comparisons between two specific second-generation antidepressants: fluoxetine and paroxetine. We selected two efficacy and three adverse event outcomes (see Table 3 above). For RA, because of the limited number of eligible head-to-head studies comparing the same individual drugs, we selected a set of studies comparing any biologics with any oral DMARDs. We instructed reviewers to treat the biologics as equivalent and the oral DMARDs as equivalent and to ignore any potential differences between drugs within a class. For RA, we selected three efficacy and two adverse event outcomes.

## Information Provided to Reviewer Participants

In October 2010, we provided reviewers with a summary table for each of the 10 exercises. This table contained information that we considered essential for completing the exercises. Specifically it provided: the relevant key question from the original CER; the treatment outcome being measured; the drug treatments being compared; and, for each study, the study design, number of participants, study quality (good or fair—none of the studies included in the exercise was rated as poor quality), and analysis results (Appendix A). We provided reviewers with other essential materials, including detailed instructions on how to complete the exercises (Appendix B), the chapter of the Methods Guide on grading the strength of a body of evidence,2 and background documents to provide baseline knowledge of MDD and RA, including descriptions of the disease conditions, treatment mechanisms and outcomes measures that would be examined in the exercises. We also sent reviewers supplemental materials; these included evidence tables and full-text articles for each study in the exercises. We instructed participants to use the supplemental materials if they wished; however, we designed the exercises so that they could be completed based on the summary tables and other essential materials and strength of evidence guidance document alone.

## Participants

We invited all EPC Directors and our AHRQ Task Order Officer to nominate pairs of reviewers who were each experienced in evaluating strength of evidence. They did not need to have background knowledge of MDD or RA and could not have participated in the original CERs from which the data were obtained. A convenience sample consisting of 22 participants (11 pairs of reviewers) participated in the exercises. Two reviewers were from AHRQ; 20 came from nine EPCs, with eight EPCs each having two reviewers and one EPC having four, (see acknowledgments). To replicate “real world” or “real EPC” practices, we organized the commonly used approach for “dual assessment.” Initially, each reviewer at a given institution independently completed each of the exercises; subsequently, the two reviewers—i.e., a “pair”—reconciled their independent responses. (For the one EPC with four reviewers, the EPC established the “pairs.”)

## Data Collection

We conducted the data collection effort during October and November 2010. The project team created electronic response forms to collect information from reviewers through ZipSurvey™, an online survey program. We used the electronic response forms to collect three types of information from the 22 reviewers: (1) background information on reviewers--their experience with conducting systematic reviews and grading strength of evidence and whether they had been trained as a physician; (2) domain scoring and strength of evidence grading results; and (3) qualitative feedback on conducting the assessment. The 11 pairs of reviewers also used the electronic response forms to submit their reconciled evaluations and any feedback to us.

For each of 10 exercises, we asked reviewers to complete two steps:

1. Score the four “required” strength of evidence domains (risk of bias, consistency, directness, and precision), separately for RCTs and observational studies, and then
2. Use this information to develop one overall strength of evidence grade for each outcome.

Reviewers were also asked to assess the difficulty of assigning a score for each domain in each exercise using a five level graduated scale that ranged from “Very Easy” to “Very Difficult.” If reviewers assessed a domain score as being either “Difficult” or “Very Difficult,” they were directed to a text box to elaborate on their response.

We also asked reviewers to provide a summary of their results for each exercise; this included noting whether one of the treatment arms was considered superior and important similarities or differences among studies. As above, we asked them to distinguish findings for RCTs and observational studies, if applicable.

Finally, we solicited reviewers’ feedback on their overall experience in assigning domain scores and a strength of evidence grade for each exercise. Reviewer pairs were asked to state the process of reconciliation that they used, to comment on any domains or outcomes that they found especially difficult to reconcile, and to provide any other feedback that they thought would be useful.

## Data Synthesis and Analysis

We calculated two summary statistics to describe agreement among reviewers on each of the four domains and the overall strength of evidence grade. Because reviewers were given a predetermined set of choices, for analytic purposes we were able to transcribe domain scores and overall strength of evidence grades into numeric responses and analyze results quantitatively.

We computed the summary statistics for each domain separately across RCT studies (10 exercises) and observational studies (6 exercises). Each summary statistic for the strength of evidence grades was based on all studies in all 10 exercises.

### Agreement on Rating Across Reviewers

The first summary measure is the first-order agreement coefficients (AC1 statistic, for alternative chance-correlated coefficient),33 which measures the agreement on the rating score among all reviewers across all relevant exercises. The AC1 statistic is a summary measure for inter-rater reliability tests with multiple raters; it is similar to the commonly used kappa statistic.34

We selected the AC1 statistic over the kappa statistic because of the concerns about the so-called “kappa paradox,” where high agreement can accompany low kappa scores.35 AC1 overcomes this paradox by adjusting for chance agreement; it is considered an alternative and appropriate measure of inter-rater reliability.

The AC1 score ranges from −1.00 (no agreement) to 1.00 (100 percent agreement). We also calculated the 95% confidence interval (CI) corresponding to the estimate.

To assist in describing and interpreting the AC1 statistic, we adopted the scale developed by Landis and Koch4 for interpreting the kappa statistic.4,5 We describe six levels of AC1 agreement as follows: <0 (less than chance agreement); 0.01–0.20 (slight agreement); 0.21–0.40 (fair agreement); 0.41–0.60 (moderate agreement); 0.61–0.80 (substantial agreement); and 0.81–0.99 (almost perfect agreement).

### Agreement on Difficulty Across Reviewers

The second summary statistic measures agreement among reviewers that it was “difficult” or “very difficult” to determine the appropriate domain score (separately for RCTs and observational studies) or the overall strength of evidence grade. We computed this summary statistic in two steps. For each domain (separately by type of study—RCT or observational) and for overall strength of evidence, we first computed the percentage of reviewer ratings of difficult or very difficult for each of the exercises. We averaged these percentages across all exercises to produce a summary statistic, and we then calculated the standard deviation of the summary statistic across the exercises. In addition, we computed the correlation coefficient between the percentage of reviewers who agreed on each domain score and the percentage of reviewers who considered the rating exercise to be difficult or very difficult.

### Prediction of Strength of Evidence Grade

We used logistic regression analysis to assess the relationship between domain scores and the strength of evidence grade at the individual-reviewer level. For these analyses, we used the SUDAAN MULTILOG procedure with the generalized estimating equation option (GEE) to control for repeated measures from the same reviewer. We estimated four models that were determined a priori. They differed in whether the dependent variable was an actual strength of evidence grade or a level of agreement on the strength of evidence grade and, secondarily, whether the data set comprised only six or all 10 exercises. Specifically they were:

- Model 1, a multinomial logistic regression model predicting strength of evidence grade by domain scores. The model included results from just the six exercises that included both RCTs and observational studies. The outcome (dependent variable) was the strength of evidence grades: insufficient; low; or moderate/high (combined as the comparison). This model had 131 observations (22 raters times 6 exercises, with 1 observation missing) and 12 independent variables, namely each of the domain scores, separately for RCTs and observational studies.
- Model 2, a modification of the above multinomial logistic regression model predicting strength of evidence grade by domain scores. This model included results from all 10 exercises by adding a dummy variable indicating whether an exercise had included observational studies, in addition to 6 independent variables for each of the RCT domain score ratings. It included 219 observations (22 raters times 10 exercises; 1 observation missing).
- Model 3, a logistic regression model predicting agreement on strength of evidence grade by agreement on domain scores. Agree was calculated as a dichotomous variable that was coded as 1 when the reviewer’s response was in agreement with the most popular response among all reviewers; otherwise it was coded as 0. The model (like Model 1) includes results from just the six exercises that included RCTs and observational studies: 131 observations (1 observation missing) and 8 independent variables. The outcome (dependent variable) was agree; disagree (comparison) on the strength of evidence grade. The independent variables were agree; disagree (comparison) on each of the domain scores, separately for RCTs and observational studies.
- Model 4, a modification of the above logistic regression model predicting agreement on strength of evidence grade by agreement on domain scores. This model (like Model 2) included results from all 10 exercises by adding a dummy variable indicating whether an exercise included observational studies. It included 219 observations and 5 independent variables.

### Subgroup Analyses of Independent Reviewer Assessments

We conducted subgroup analyses to examine whether reviewers’ responses differed across domain scores and strength of evidence grades by several variables: clinical condition (MDD vs. RA); type of outcome (benefit vs. harm); academic training of the reviewer (physician vs. nonphysician); years of experience in conducting systematic reviews; and years of experience in grading strength of evidence. We combined all the reviewers’ ratings across all exercises and computed the average agreement, stratified by subgroup. We tested whether the likelihood of a reviewer’s response agreed with the most popular response, through logistic regression analysis using the SUDAAN MULTILOG procedure with GEE to control for repeated measures from the same reviewer.

In each subgroup analysis, we specified the reviewer’s response as the dependent variable (coded as 1 if the response was the most popular response and 0 otherwise) and the stratification (subgroup) of interest (i.e., clinical topic, outcome type, academic training, and two measures of experience) as the one independent variable. For example, the analysis examining the effect of being a physician on the agreement for each domain score was specified as follows:

logit (uij) = α + β MD_indicator_ij_ i = 1 to 22 raters, j = 1 to 10 for RCT studies and 1 to 6 for observational studies; where

u_ij_ is 1 if the rater’s response for the domain agreed with the most popular response and 0 otherwise,

MD_indicator_ij_ is 1 if the rater i for the study j is a physician and 0 otherwise,

α is the intercept, and

β is the slope of each logit model.

In addition to examining the significant results from each of the logistic regression analyses, we also examined patterns of percentage agreement (regardless of statistical significance) because of concerns about limitations in power resulting from a small sample size.

### Reconciliation Across Reviewer Pairs

We examined changes in each independent reviewer’s domain scores and in strength of evidence grades following reconciliation with his or her partner. We assigned a numeric value to each of the domains/strength of evidence responses for each reviewer and for each pair. For the consistency domain, we combined scores of inconsistent and unknown for this analysis because they were considered worse scores than consistent, but the two could not be clearly ranked with each other. A higher value indicated a better score and a lower value a worse score as follows:

- Risk of bias: Low = 3, Medium = 2, High = 1;
- Consistency: Consistent = 2, Inconsistent or Unknown = 1;
- Directness: Direct = 2, Indirect = 1;
- Precision: Precise = 2; Imprecise = 1;
- Strength of evidence: High = 4, Moderate = 3, Low = 2, Insufficient = 1.

For each domain, we then subtracted each individual’s score from the reconciled (‘pairs’) score, yielding two “difference scores.” Next, we summed these two difference scores for each pair and classified the summed value into three change groups: agree (i.e., no change), better score, or worse score. Results for domain scores for RCT studies and strength of evidence were based on 11 pairs evaluating 10 outcomes (N=110). Results for domain scores for observational studies were based on 11 pairs evaluating 6 outcomes (N=66).

The majority of the change groups with a value of zero constituted the case in which the numeric value of the reconciled score and both of the individual scores was equal, indicating that the two individuals agreed on the domain response. As illustrated in Table 4 (example 3), both reviewers scored risk of bias as 2, so subtracting each of their scores from the reconciled score, which by definition was 2, yielded a difference of zero. We put these into the “agree” group. In a few cases, however, the reconciled score was the mid-point of the two individual scores (example 4). For example, a reconciled score had a value 2 whereas the two individual scores were 1 and 3. Because this case has no clear direction of change, we grouped it also with the “agree” group.

Table 4 Illustration of calculation of change scores

Example | Reconciled Score | Score From Reviewer #1 | Score From Reviewer #2 | Difference (Change) Score | Direction of Change
1 | 3 | 1 | 2 | (3−1) + (3−2) = 3 | Better score
2 | 2 | 3 | 2 | (2−3) + (2−2) = −1 | Worse score
3 | 2 | 2 | 2 | (2−2) + (2−2) = 0 | Agree/No change
4 | 2 | 1 | 3 | (2−1) + (2−3) = 0 | Agree/No change

Finally (see Table 4), a change score is positive (better) when the reconciled score was a larger value than either one or both of the individual scores; that is, this case indicated that reconciled score changed toward a “better” score direction. Similarly, a negative change score indicated that the move was toward a “worse” direction.

### Qualitative Analyses

We qualitatively synthesized the reasons that reviewers found particular domain scoring and strength of evidence grading difficult and present these findings in the results sections containing corresponding data from the inter-rater reliability testing. We also documented the approaches that reviewer pairs used to resolve disagreements. This information is intended to provide contextual insights into the results across reviewers.