# Introduction

## Background

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-based Practice Center (EPC) program, sponsors Comparative Effectiveness Reviews (CERs) and other systematic reviews (SRs) of the literature. To advance this effort, AHRQ developed methodological guidance and supported related research to enhance the scientific rigor of these reviews.1 AHRQ’s guidance encompasses many of the required tasks of a review.

Chapters of the Methods Guide for Effectiveness and Comparative Effectiveness Reviews (Methods Guide) cover a wide array of topics. Among them are developing analytic frameworks to describe the relationship between treatment options and health outcomes; searching for relevant evidence; using observational studies in addition to randomized trials; evaluating the risk of bias (quality) of individual included studies; quantitatively synthesizing evidence; grading the strength of the evidence in relation to outcomes; and assessing the applicability of findings from the included studies.

The guidance on the methodological approach to employ in completing these various tasks is developed through working groups, comprised primarily of expert practitioners from the independent EPCs. One such cross-EPC team developed the chapter on grading the strength of evidence related to therapeutic interventions, which was published in 2010 as definitive guidance for EPCs.2

We report here on an evaluation of the inter-rater reliability of the strength of evidence guidance when used by experienced reviewers across the EPCs. We conducted this research starting in 2010 (after the publications above were available). Our primary goal was to determine whether different teams of reviewers would reach similar conclusions on the strength of evidence when presented with the same information about studies included in a CER. Our second goal was to gain a greater understanding of the relative role of each of the criteria (referred to as domains) that are evaluated in developing a strength of evidence grade.

## AHRQ EPC Approach to Evaluating Strength of Evidence

The strength of evidence grade is a key indicator of a review team’s level of confidence that the studies included in the review collectively reflect the true effect of an intervention on a health outcome. The AHRQ Methods Guide chapter for grading the strength of evidence instructs reviewers to score the body of evidence in relation to each major outcome (e.g., benefits and harms) and each main comparison (e.g., intervention A vs. intervention B) in relation to each key question of the review.2

First, two independent reviewers evaluate (score) critical domains. The four required domains include the risk of bias of included studies, the consistency of the evidence, the directness of the evidence, and the precision of the estimates (Table 1). Four additional domains that can be scored if reviewers consider them to be integral to making a final evaluation include dose-response association, plausible confounding that would decrease observed effect, strength of association/magnitude of effect, and publication bias. The Methods Guide recommends scoring each of the domains separately for randomized controlled trials (RCTs) and observational (nonrandomized) studies that are evaluated for each outcome. Disagreements between the two reviewers in their decisions concerning domains scores are resolved through consensus or adjudication by a third reviewer.

Table 1 Required domains in the AHRQ EPC approach to grading strength of evidence^*^

Domain | Key Elements | Score Bolded score: raises strength of evidence Italicized score: lowers strength of evidence
Risk of bias | Degree to which included studies for specified outcome & comparison have a high likelihood of adequate protection against bias (i.e., good internal validity), assessed through two main elements: study design and aggregate quality of included studies being considered (based on quality or risk of bias rating of individual studies [good/fair/poor]). | Scored as one of three levels: Low Medium High If included studies differ in risk of bias, greater weight can be given to those with lower risk
Consistency | Degree to which reported effect sizes of included studies for specified outcome and comparison have same direction of effect. Assessed by two main elements: effect sizes have same sign (i.e., are on same side of no effect) and range of effect sizes is narrow | Scored as one of three levels: Consistent: no inconsistency Inconsistent: non-overlapping confidence intervals, significant unexplained clinical or statistical heterogeneity, statistically significant effect sizes in opposite directions Unknown or not applicable: includes single-study evidence
Directness | Whether the evidence links the intervention directly to a health outcome. If two treatments are compared, directness implies that head-to-head trials measure the most important outcome. Evidence can be indirect in two ways:; 1. Uses intermediate or surrogate outcomes rather than ultimate health outcomes;; 2. Uses two or more bodies of evidence to compare interventions A and B without having head-to-head studies of A vs. B | Scored as one of two levels: Direct Indirect: specify which of the two types, or both if applicable. Note potential weaknesses caused by indirect evidence or analysis
Precision | Degree of certainty surrounding an effect estimate for a specified outcome and comparison. If meta-analysis is used, it is the confidence interval around the summary effect size. | Scored as one of two levels: Precise: clinically useful conclusion Imprecise: would not allow for clinically distinct conclusions such as clinical inferiority

* From Owens, et al., 2010.^2^

Finally, for each major outcome and each major comparison (e.g., intervention A vs. intervention B), EPCs then aggregate domains scores into a single strength of evidence grade (Table 2). The Methods Guide does not dictate one way for EPCs to incorporate the multiple domain scores to arrive at the overall strength of evidence grade in relation to an outcome. EPCs can use the algorithm developed by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) working group,3 their own weighting (e.g., numeric) system, or a qualitative approach. The only requirement is transparency; EPCs must clearly explain their rationale for aggregating the domains in a single strength of evidence grade.

Table 2 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

* From Owens, et al., 2010.^2^

The authors of the Methods Guide chapter on strength of evidence concluded that refinements to the current guidance would likely warrant cross-EPC attention and additional empirical work in the years ahead. Thus, the present guidance is understood to be open for modification as more experience with research into these issues accumulates.

## Background: Quality of Evidence Reliability Project Conducted by the GRADE Working Group

Several years ago, the GRADE Working Group tested the inter-rater reliability of a pilot version of their approach to grading strength of evidence (referred to by GRADE as quality of evidence) and recommendations.3 In that study, researchers provided an evidence profile to reviewers, consisting of two tables. One table presented a quality assessment of the available information for each outcome and included the following: the number of studies that were included to evaluate the outcome, the type of study design (RCT or observational), the quality of each included study, consistency of results across studies, and directness of the available evidence. The second table presented a summary of findings for each outcome: data on the number of patients and events and measures of the relative effect of treatments.

Seventeen reviewers evaluated 12 outcomes (i.e., specific research questions) drawn from a single systematic review. The reviewers graded the strength of evidence for each evidence profile based solely on the information in the evidence profiles. Kappa agreement among raters for the 12 outcomes was fair (κ=0.27 [standard error (SE), 0.015]), ranging from agreement slightly worse than chance for four outcomes (negative kappa values) to a high of κ=0.823 for one outcome.4,5

## Study Objectives

Our project focused on inter-rater reliability testing of the two main components of the AHRQ approach to the task of grading strength of evidence for specific outcomes in relation to key questions: (1) scoring evidence on the four required domains (risk of bias, consistency, directness, and precision) and (2) developing an overall strength of evidence grade, given the scores for these four individual domains.

Thus, our research focused on key questions concerning the performance of these two main tasks:

### Key Question 1. Domain Scores

#### Independent Reviewers

- How consistent are domain score assessments conducted by individual independent reviewers (i.e., those done separately by a single reviewer)? Do inter-rater reliability calculations indicate patterns of reasonable agreement across reviewers?
- Are any of the required domains more difficult or problematic for independent reviewers to assess than others?
- Are domain scores for observational studies more difficult or problematic for independent reviewers to assess than those for RCTs?

#### Reviewer Pairs

- How consistent are domain scores that are the result of reconciliation by pairs of reviewers (i.e., assessment of scores on domains from two independent reviewers that are reconciled) across pairs of reviewers? Is the level of agreement among scores assessed by reconciled pairs greater than the level of agreement among domain scores assessed by independent reviewers?
- When reviewer pairs disagree on a domain score, in what direction do the reviewers generally reconcile their disagreements (e.g., toward better or toward worse domain scores)?
- Does the mechanism used by reviewer pairs to resolve disagreements in domain scores affect the agreed on score (i.e., does it matter whether the disagreement is resolved through consensus discussion between the two independent reviewers or through adjudication by a third reviewer)?

### Key Question 2. Overall Strength of Evidence Grade

#### Independent Reviewers

- How consistent are strength of evidence grade assessments conducted by individual, independent reviewers (i.e., those done separately by a single reviewer)? Do inter-rater reliability calculations indicate patterns of reasonable agreement?
- Are particular domain scores more likely than others to be predictive of agreement in the overall strength of evidence grade?
- Does agreement in strength of evidence grades differ by whether the evidence consists solely of RCTs or a combination of RCTs and observational studies?
- Does using different methods for combining domain scores into a single, overall strength of evidence grade result in a meaningful difference regarding the ultimate grade or in the time and effort expended? Possible methods include:
  ○ The weighting system applied through using the GRADE algorithm (i.e., the approach promulgated by the GRADE Working Group),
  ○ The EPC’s own “numeric” or quantitative” weighting system, or
  ○ The EPC’s own “qualitative” approach to weighting or combining domain scores?

#### Reviewer Pairs

- How consistent are strength of evidence grades that are the result of reconciliation by reviewer pairs (i.e., assessment of grades from two independent reviewers that are reconciled) across pairs of reviewers? Is the level of agreement among strength of evidence grades assessed by reconciled pairs greater than the level of agreement among strength of evidence grades assessed by independent reviewers?
- When reviewer pairs disagree on strength of evidence grades, in what direction do the reviewers generally reconcile their disagreements (e.g., toward better or toward worse strength of evidence grades)?
- Does the mechanism used by reviewer pairs to resolve disagreements in strength of evidence grades affect the agreed-on grade (i.e., does it matter whether the disagreement is resolved through consensus discussion between the two independent reviewers or through adjudication by a third reviewer)?

Our analytic framework (Figure 1) displays linkages between our population (individual independent reviewers and reviewer pairs) and outcomes (agreement on domain scores and overall strength of evidence grades). We present reviewers’ characteristics (background and experience) that may affect their independent scores and resulting grades; we also note reviewer pairs’ reconciliation approach because it may affect their reconciled scores and grades. We also present factors that may influence level of agreement across independent reviewers and reviewer pairs (differences in reviewers’ judgment, training, and methodological approach). The discussion chapter is organized to synthesize our conclusions in relation to our Key Questions and comment on the relative influence of these three factors.

Figure 1 Analytic framework for inter-rater reliability in EPC approach to grading strength of evidence

Figure 1: This figure is an analytic framework depicting the key questions (KQs) linking the study population (independent reviewers and reviewer pairs) and the outcomes of the strength of evidence reliability test project (agreement on domain scores and strength of evidence grades). Independent reviewer characteristics are depicted as: clinical training, epidemiologic or methodologic training, experience in conducting systematic or comparative effectiveness reviews, and experience in grading strength of evidence. Factors influencing agreement on domain scores include: judgment (a decision based on clear and sufficient detail in guidance and the same interpretation of guidance criteria and how to apply it to available evidence about comparisons of outcomes to receive domain scores); training (understanding of how to use the guidance correctly to evaluate the evidence) and methodological approach (same choice of criteria and instructions used to make judgments). Factors influencing agreement on overall strength of evidence grade include: judgment (a decision based on clear and sufficient detail in guidance and the same interpretation of guidance criteria and how to apply it to available evidence about comparisons of outcomes to receive strength of evidence grade); training (understanding of how to use the guidance correctly to evaluate the evidence) and methodological approach (same choice of criteria and instructions used to make judgments including the same approach to weighting domain scores to reach judgment—GRADE working group, EPC’s own qualitative approach, EPC’s own quantitative approach, hybrid approach); and same approach to combining domain scores when evidence is a combination of observational studies and randomized controlled trials (RCTs). The reviewer pair’s reconciliation process is depicted as either a consensus of independent reviewers or adjudication by a third party. KQ1 links individual independent reviewer’s domain scores with agreement on domain scores among all independent reviews. KQ1 also links reviewer pair’s domain scores with agreement on domain scores among all reviewer pairs. KQ2 links individual independent reviewer’s strength of evidence grades with agreement on strength of evidence grades among all independent reviews. KQ2 also links reviewer pair’s strength of evidence grades with agreement on strength of evidence grades among all reviewer pairs.