# Executive Summary

## Introduction

The Agency for Healthcare Research and Quality (AHRQ), through its Evidence-based Practice Center (EPC) program, sponsors Comparative Effectiveness Reviews (CERs) and other systematic reviews (SRs). To advance this effort, AHRQ developed methodological guidance encompassing many of the steps of such reviews. We focus here on the guidance on grading the strength of evidence related to therapeutic interventions, which was published in 2010 as definitive guidance for EPCs.

The strength of evidence grade is a key indicator of a review team’s level of confidence that the studies included in the review collectively reflect the true effect of an intervention on a health outcome. The AHRQ Methods Guide chapter for grading the strength of evidence instructs reviewers to score the body of evidence in relation to each major outcome and each major comparison in relation to each key question of the review.

Our project focused on inter-rater reliability testing of the two main components of the AHRQ approach to the task of grading strength of evidence for specific outcomes in relation to key questions: (1) scoring evidence on the four required domains (risk of bias, consistency, directness, and precision) and (2) developing an overall strength of evidence grade, given the scores for the individual domains.

Thus, our research focused on key questions concerning the performance of these two main tasks among independent reviews and reconciled pairs of reviewers. Our specific key questions are presented with their corresponding results.

## Methods

We conducted the inter-rater reliability testing using data obtained from two published CERs focusing on two distinct medical indications and drug treatments: second-generation antidepressants for the treatment of major depressive disorder (MDD) and disease-modifying antirheumatic drugs (DMARDs) for the treatment of rheumatoid arthritis (RA). From the data in these reviews, the study team designed 10 exercises; all 10 included RCTs, and 6 of the 10 included one or more observational studies. Using the same terminology as is used in the AHRQ Methods Guide chapter, observational studies include nonrandomized trials, cohort, cross-sectional and case-control studies. Also, we provided the risk of bias of individual studies as a quality assessment (good, fair, or poor) because the original reviewers used this metric. For outcomes, we specified five positive outcomes (benefits) and five harms (adverse effects) of the therapies under examination.

Eleven pairs of reviewers (22 participants) participated in the exercises: two from AHRQ and 20 from nine EPCs. To replicate “real world” or “real EPC” practices, we aimed for a dual assessment in which each independent reviewer (at a given organization) was also paired with a colleague at that institution. Thus, initially, each reviewer independently completed each of the 10 exercises; subsequently, the two reviewers—i.e., the “pair”—reconciled their independent responses through consensus or mediation by a third reviewer.

Reviewers were provided with the relevant key questions from the original CER; the treatment outcome being measured; the drug treatments being compared; and for each study, the study design, number of participants, study quality, and analysis results. One of the exercises included results from a meta-analysis. For each exercise, reviewers scored the four “required” strength of evidence domains (risk of bias, consistency, directness, and precision), separately for RCTs and observational studies. Then they used these domain-specific scores (and perhaps other information) to determine one grade for the overall strength of evidence for each outcome.

We also asked each reviewer to assess the difficulty of assigning a score for each domain in each exercise. They used a graduated scale of levels that ranged from “Very Easy” to “Very Difficult.”

For analytic purposes, we transcribed domain scores and overall strength of evidence grades into numeric responses and analyzed results quantitatively. We calculated two summary statistics to describe agreement among reviewers:

- The AC1 statistic (alternative chance-correlated coefficient, ranging from −1.00 to 1.00) measuring the agreement on the rating score among all reviewers across all exercises; and
- A statistic measuring agreement among reviewers that it was difficult or very difficult to determine the appropriate rating.

We used logistic regression analysis to assist in describing the relationship between domain scores and the strength of evidence grade, both in relation to the specific grade selected (i.e., insufficient; low; or moderate/high [combined as the comparison]) and level of agreement among reviewers in the grade selected. We examined the change in independent reviewer ratings following the reconciliation with the ratings of his or her partner.

To provide contextual insights into our quantitative analyses, we qualitatively synthesized the reasons that reviewers found particular rating exercises difficult.

## Results

Overall, the level of agreement for domain scores was generally better across reviewers in their evaluations of RCTs than observational studies; exceptions were individuals’ ratings of precision and pairs of reviewers’ evaluations of directness. Likely because of the small sample sizes, virtually none of the differences in agreement reached statistical significance; the sole exception was the risk of bias domain. We did not discern a pattern in the correlation between agreement among individual reviewers and the percentage of reviewers who found the rating activity difficult or very difficult. Table A summarizes inter-rater testing results.

Table A Inter-rater reliability results by domain and overall grade

Domain/Strength of Evidence | Study Design | Number of Exercises | AC1 Agreement Across Independent Reviewers (95% CI) | Percentage of Independent Reviewers (SD) Describing Rating as Difficult or Very Difficult | Correlation Between Independent Reviewer Ratings on Agreement and Difficulty | Agreement Across Reconciled Pairs of Reviewers: AC1 (95% CI)
Risk of bias | RCT | 10 | 0.67(substantial) (0.61 to 0.73) | 3.2% (3.1%) | r=0.21 | 0.65 (substantial) (0.56 to 0.73)
Risk of bias | Observational | 6 | 0.11 (slight) (0.05 to 0.18) | 9.8% (6.0%) | r=−0.33 | 0.22 (fair) (0.13 to 0.32)
Consistency | RCT | 10 | 0.51 (moderate) (0.34 to 0.67) | 8.7% (9.0%) | r=−0.92 | 0.70 (substantial) (0.51 to 0.90)
Consistency | Observational | 6 | 0.40 (fair) (0.13 to 0.66) | 6.1% (8.0%) | r=−0.74 | 0.55 (moderate) (0.22 to 0.89)
Directness | RCT | 10 | 0.73 (substantial) (0.60 to 0.87) | 4.1% (4.0%) | r=0.09 | 0.78 (substantial) (0.64 to 0.92)
Directness | Observational | 6 | 0.48 (moderate) (0.32 to 0.64) | 6.1% (8.5%) | r=−0.80 | 0.78 (substantial) (0.52 to 1.02)
Precision | RCT | 10 | 0.23 (fair) (0.11 to 0.35) | 17.8% (8.4%) | r=0.24 | 0.47 (moderate) (0.17 to 0.77)
Precision | Observational | 6 | 0.31 (fair) (0.06 to 0.56) | 14.5% (3.4%) | r=0.09 | 0.38 (fair) (0.06 to 0.70)
Strength of Evidence | All exercises | 10 | 0.20 (slight) (0.16 to .25) | 19.6% (11.0%) | r=0.06 | 0.24 (fair) (0.14 to 0.34)
Strength of Evidence | RCTs only | 4 | 0.22 (fair) (0.17 to 0.28) | 14.7% (6.8%) | r=−0.09 | 0.30 (fair) (0.17 to 0.43)

Abbreviations: AC1 = alternative chance-correlated coefficient = an alternative to a kappa statistic; CI = confidence interval; r = correlation; RCT = randomized controlled trial; SD = standard deviation.

### Key Question 1: Domain Scores Among Independent Reviewers

#### How consistent are domain score assessments conducted by individual independent reviewers (i.e., those done separately by a single reviewer)? Do inter-rater reliability calculations indicate patterns of reasonable agreement across reviewers?

The level of independent reviewer inter-rater agreement for domain scores varied considerably—from substantial for RCT risk of bias (AC1 = 0.67) and directness (AC1 = 0.73) to slight for observational study risk of bias (AC1 = 0.11). Agreement on all other domains was either moderate or fair.

#### Are any of the required domains more difficult or problematic for independent reviewers to assess than others?

For both RCTs and observational studies, agreement on precision was only fair. Reviewers expressed a desire for greater guidance when they could not rely on a meta-analysis and were faced with such problems as statistical significance expressed through p-values but not confidence intervals, a variety of differently measured outcomes, and nonsignificant findings. As presented in Table A, with the exception of the precision domain, only a small percentage of reviewers commented that they found rating specific domains to be “difficult” or “very difficult.”

#### Are domain scores for observational studies more difficult or problematic for independent reviewers to assess than those for RCTs?

Based on generally poorer inter-rater reliability results, we conclude that domain assessments for observational studies were more problematic than for RCTs. The particularly low agreement (slight) in relation to the risk of bias assessment of observational studies most likely relates to reviewers’ not receiving sufficient guidance concerning the criteria the project CER teams had originally used for determining the quality of the studies and the different methodological approaches of the reviewers themselves.

### Key Question 1: Domain Scores Among Reviewer Pairs

#### How consistent are domain scores that are the result of reconciliation by pairs of reviewers (i.e., assessment of scores on domains from two independent reviewers that are reconciled) across pairs of reviewers? Is the level of agreement among scores assessed by reconciled pairs greater than the level of agreement among domain scores assessed by independent reviewers?

Agreement on domain scores for reconciled reviewer pairs overall was as good as or better than it was for individual independent reviewers. Agreement on three of the four RCT scores was substantial (risk of bias, consistency, and directness). Agreement on appropriate precision domain scores was poorer than for the other domains, but it improved from fair to moderate for pairs. Agreement on domain scores for observational studies across reconciled pairs also improved in all domains except precision, but agreement was substantial only for directness. Based on these findings, we conclude that the reconciliation process is a critical step in domain scoring.

#### When reviewer pairs disagree on a domain score, in what direction do the reviewers generally reconcile their disagreements (e.g., toward better or toward worse domain scores)?

The direction of change in scores when a pair of reviewers had to settle a difference (i.e., had to reconcile their original scores) was inconsistent across domains and were reconciled to be “better” or “worse” in no obvious pattern.

#### Does the mechanism used by reviewer pairs to resolve disagreements in domain scores affect the agreed on score (i.e., does it matter whether the disagreement is resolved through consensus discussion between the two independent reviewers or through adjudication by a third reviewer)?

Only one pair of reviewers adjudicated differences by using a third party. Therefore, we had insufficient data to evaluate the effect of using consensus discussion versus a third party adjudicator on level of agreement across pairs.

### Key Question 2: Strength of Evidence Grades Among Independent Reviewers

#### How consistent are strength of evidence grade assessments conducted by individual, independent reviewers (i.e., those done separately by a single reviewer)? Do inter-rater reliability calculations indicate patterns of reasonable agreement?

Agreement on independent reviewer strength of evidence grades overall was generally poorer than for domain scores. For the overall strength of evidence grades, inter-rater reliability agreement was slight among individual reviewers (AC1=0.20). Almost 20 percent of reviewers found the exercise of rating the strength of evidence to be difficult or very difficult.

#### Are particular domain scores more likely than others to be predictive of agreement in the overall strength of evidence grade?

We found that neither agreement on domain scores nor agreement about the level of difficulty that reviewers ascribed to evaluating particular domains predicted the overall grades.

#### Does agreement in strength of evidence grades differ by whether the evidence consists solely of RCTs or a combination of RCTs and observational studies?

Inter-rater reliability was not appreciably better when we considered only the four exercises limited to RCTs (AC1=0.22) as compared with all exercises (AC1=0.20).

When evidence was limited to RCT studies (four exercises), better strength of evidence grades of moderate/high (compared with both insufficient and low) were related to RCT domain scores’ being considered consistent and precise. Because all RCT studies were presented as fair quality and were head-to-head trials, it is not surprising that the risk of bias and consistency domains were not predictors of the final strength of evidence grade.

Based on results from all 10 exercises, the inclusion of observational studies, in addition to RCTs, in an exercise was a strong predictor of a poorer strength of evidence grade —namely, either insufficient or low versus moderate/high.

Looking at the relationship between specific observational studies domain scores and strength of evidence grades, we found that observational study evidence being considered low risk of bias was significantly related to strength of evidence being graded as insufficient (but not low) versus moderate/high. This counterintuitive finding may be related to the findings in the two exercises with good-quality observational studies conflicting with the findings from the RCT evidence. By considering the observational studies as well as the RCT data, reviewers might reasonably have concluded that they could not reach a conclusion about the body of evidence. Also, consistency of observational studies data was positively related to the strength of evidence grade being moderate or high versus insufficient. This finding would seem to reflect reviewers’ consideration of observational studies as secondary evidence that supports RCT findings when the direction of the findings is clear and not in conflict.

#### Does using different methods for combining domain scores into a single, overall strength of evidence grade result in a meaningful difference regarding the ultimate grade or in the time and effort expended?

Possible methods include:

- The weighting system applied through using the GRADE algorithm (i.e., the approach promulgated by the GRADE Working Group),
- The EPC’s own “numeric” or quantitative” weighting system, or
- The EPC’s own “qualitative” approach to weighting or combining domain scores?

Methodological approaches to grading the strength of evidence were insufficiently described to be distinctly categorized and evaluated in relation to strength of evidence grading decisions.

### Subgroup Analyses of Independent Reviewer Assessments of Domain Scores and Strength of Evidence Grades

Five subgroup analyses compared level of agreement by clinical condition (MDD versus RA), type of outcome (benefit versus harm), reviewers’ experience in conducting systematic reviews, experience in evaluating strength of evidence, and academic training (physician versus nonphysician). Few differences were significant, and many were small.

Reviewer agreements by clinical condition and by type of outcome (benefits versus harms) were generally small and lacked informative patterns.

Reviewers with greater experience in conducting systematic reviewers (six of eight comparisons) and those with greater experience in evaluating strength of evidence (four of eight comparisons) were more likely to agree on domain scores. In contrast, reviewers with less experience (on both measures) were more likely to agree on strength of evidence grades than reviewers with greater experience.

We found few differences in agreement based on reviewers’ type of academic training (i.e., physician or nonphysician). Because all participants were experienced reviewers from EPCs and because we did not evaluate background knowledge of the particular clinical conditions, we concluded that this distinction likely did not capture differences among reviewers in clinical and methodological expertise.

### Key Question 2: Strength of Evidence Grades Among Reviewer Pairs

#### How consistent are strength of evidence grades that are the result of reconciliation by reviewer pairs (i.e., assessment of grades from two independent reviewers that are reconciled) across pairs of reviewers? Is the level of agreement among strength of evidence grades assessed by reconciled pairs greater than the level of agreement among strength of evidence grades assessed by independent reviewers?

Approximately 46 percent of strength of evidence grades were the same across independent reviewer pairs and so did not need to be reconciled.

Agreement on strength of evidence grades across reconciled pairs, compared with agreement for independent reviewers, improved modestly, from slight to fair, across exercises that had evidence from both RCTs and observational studies. It remained fair across exercises with only RCT evidence.

#### When reviewer pairs disagree on strength of evidence grades, in what direction do the reviewers generally reconcile their disagreements (e.g., toward better or toward worse strength of evidence grades)?

Final strength of evidence grades that needed to be reconciled were no more likely to be changed to a better (higher) or a worse (lower) grade. Approximately 25 percent were reconciled to a higher grade and approximately 30 percent to a lower grade. The pattern of reconciliation to better or worse final strength of evidence grades was not generally related to which of the two grades were being reconciled.

#### Does the mechanism used by reviewer pairs to resolve disagreements in strength of evidence grades affect the agreed-on grade (i.e., does it matter whether the disagreement is resolved through consensus discussion between the two independent reviewers or through adjudication by a third reviewer)?

We lacked sufficient data to determine whether the mechanism used to resolve disagreements between the two independent reviewers affected the final agreed-upon grade.

## Discussion

### Conclusions

The series of exercises we designed deliberately reflected the diversity and complexity of evidence that EPC reviewers encounter in their day-to-day evaluations. Our findings clearly demonstrate that the conclusions reached by experienced reviewers based on the same evidence can differ greatly. Consistency across reviewers can suffer when they are faced with complex bodies of evidence, especially when those data do not lend themselves to meta-analysis. Reflecting our analytic framework, we considered three factors that may have influenced the level of agreement that may have influenced the level of agreement on domain scores and final strength of evidence grades: reviewers’ methodological approach, their judgment, and training.

Based on substantial agreement in domain scores and overall strength of evidence for the one exercise based on meta-analysis results from RCTs, current methodological guidance may be generally sufficient for straightforward evaluations that can rely on quantitative tools for summarizing the available information. In contrast, levels of agreement suffered when reviewers were faced with qualitative evaluations that did not lend themselves to meta-analysis and they needed to rely more heavily on their own judgment. Of particular concern is how to deal with (a) outcomes that are evaluated through a combination of RCTs and observational studies, (b) outcomes that are evaluated through more than one measure, and (c) grading evidence that appeared to show no difference. Reviewers need additional guidance on approaches to summarizing the strength of evidence, given various domain scores and combinations of such scores.

Additional training may also be desirable. In particular, we believe that some reviewers inappropriately considered some issues within incorrect domain categories. Training could provide relatively less experienced reviewers with greater knowledge of how to approach the various steps in the grading strength of evidence task. Over time, this enhanced educational effort should improve consistency.

### Limitations

Our findings should be considered in light of several limitations: we limited the assessment to the four “required” domains in the AHRQ EPC guidance; we required reviewers to evaluate evidence about two clinical conditions for which they may have had limited or no prior knowledge; although we provided reviewers with p-values for exercises in which such information was missing, we did not calculate confidence intervals (when they were missing); and we did not give reviewers the criteria that the authors of the original CERs had applied to determine their own quality (or risk of bias) ratings of individual observational studies.

### Needed Guidance Enhancements and Future Research

We conclude that additional methodological guidance is needed, including more details and examples, supported by more training, particularly on how best to evaluate the “thornier” bodies of evidence as discussed above. However, some potential will always exist for disagreement, even among experienced reviewers. For that reason, EPC reviewer teams need to be transparent in how they have conducted this task – that is, by documenting and describing their procedures. This will help to ensure that stakeholders can be confident of their understanding of a reviewer team’s interpretation of the evidence and their ability to make decisions using such information.

Our study provided only a first approximation of reviewers’ rationales for differences in domain scores and strength of evidence decisions. Additional research is needed to identify gaps in guidance that should be filled, areas of insufficient understanding of the guidance itself and how best to overcome that deficit, and complex decisions that may still need to be left to the review team’s substantive expertise. A future reliability study could compare whether a single, more standardized approach to grading strength of evidence, particularly arriving at an overall grade from domain scores, would provide greater reliability than the varied approaches that EPCs have been permitted to use in the current guidance. If inter-rater reliability is similar when methods are constrained to stipulated approaches that are less discretionary, then such findings might indicate not only that gaps remain in both approaches but also that, for complex evaluations, no “right” approach may exist. That, in turn, highlights the importance of transparency and the need for adequate explanation that speaks to the needs of all stakeholders.