# Discussion

## Overview of the Project

We tested the inter-rater reliability of the AHRQ approach to evaluating strength of evidence. We asked two independent reviewers to provide individual domain scores and strength of evidence grades for 10 exercises and to reconcile their decisions with a partner, reflecting the process that EPCs typically use. Twenty-two reviewers from nine EPCs and AHRQ participated. We solicited comments from reviewers throughout the process to obtain insights concerning their approach to completing the exercise, the evaluations that they considered difficult, and the resulting choices that they made.

Our approach expanded in several ways on a similar empirical study conducted by members of the GRADE working group in the early 2000s.3 Like the GRADE study, we assessed agreement in the overall grade. However, we began one step earlier in the process and evaluated agreement on the criteria (i.e., domains) that the AHRQ approach requires to decide on the overall grade; these domains are risk of bias, consistency, directness, and precision. Whereas GRADE used data from one review on one disease condition, we used data from two completed comparative effectiveness reviews (CERs) to enhance the generalizability of our findings; these CERs covered different health conditions, a range of benefits, and minor to severe harms.

We sought to determine the level of consistency (i.e., agreement) in domain scores (Key Question 1) and strength of evidence grades (Key Question 2) across reviewers, both when reviewers were working independently and after they had reconciled their decisions with a partner. The 10 exercises included a mix of RCTs and observational studies. They also posed different evaluation challenges, such as heterogeneous outcome measures, indirect comparisons, precision of estimates presented through p-values only, and inconsistent results across studies. Only one exercise lent itself to a quantitative evaluation of pooled estimates through the inclusion of a meta-analysis.

### Key Question 1. Principal Findings: Domain Scores

#### Independent Reviewers

The level of independent reviewer inter-rater agreement for domain scores varied considerably from substantial for RCT risk of bias (AC1 = 0.67) and directness (AC1 = 0.73) to slight for observational study risk of bias (AC1 = 0.11). Agreement on all other domains was either moderate or fair. The high level of consistency of agreement for both these RCT assessments was most likely related to the straightforward nature of the data in the evaluations across exercises, resulting in similar reviewer judgments. All the RCT risk of bias assessments involved studies identified as fair quality; the RCT directness assessments were all head-to-head comparisons, with six of the 10 exercises including outcomes measuring ultimate endpoints of interest through one scale.

In contrast, the risk of bias assessment for observational studies was more problematic. This relates most likely to reviewers’ not receiving sufficient guidance concerning the criteria that the project CER teams had originally used for determining the “quality” of the studies, requiring reviewers to use their own judgment criteria to interpret the meaning of the scores. Some, but not all reviewers, considered the evaluation of observational studies to begin as high risk of bias, and even in the two exercises that included one good-quality and one fair-quality study, one-third of reviewers evaluated the risk of bias as high. Comments from reviewers support the conclusion that they lacked confidence in the appropriate approach for making the risk of bias assessment for observational studies.

Inter-rater agreement was greater for RCTs than observational studies, with the exception of the precision domain. For both RCTs and observational studies, agreement on precision was only fair and reviewers raised similar concerns with respect to both types of study designs. They expressed a desire for greater guidance to direct their judgments when they could not rely on a quantitative synthesis through a meta-analysis and were faced with such problems as statistical significance expressed through p-values but not confidence intervals, a variety of differently measured outcomes, and nonsignificant findings.

Reflecting these concerns related to scoring the precision domain, of all of the domain scoring decisions, reviewers were most likely to have considered scoring precision to be difficult or very difficult (18 percent of RCT and 15 percent of observational study decisions). Few reviewers considered scoring other domains to be difficult. For this reason, reviewers’ judgments of difficulty were not especially informative with respect to levels of agreement on domain scores.

#### Reviewer Pairs

Agreement on domain scores for reconciled reviewer pairs was as good as or better than it was for individual independent reviewers. Agreement on three of the four RCT scores was substantial (risk of bias, consistency, and directness). Agreement on precision domain scores was poorer than for the other domains, but it improved from fair to moderate for pairs. Agreement on domain scores for observational studies across reconciled pairs also improved in all domains except precision, but agreement was substantial only for directness.

The direction of change in scores when a pair of reviewers had to settle a difference (i.e., had to reconcile their original scores) was inconsistent across domains. That is, they were reconciled to be “better” or “worse” in no obvious pattern. We had insufficient data to evaluate the effect of using consensus discussion versus a third party adjudicator on level of agreement across pairs.

Based on these findings, we conclude that the reconciliation process is a critical step in domain scoring. We do not have sufficient data to report on differences in agreement based on methodological approaches that the individuals in each of the pairs might have followed. Nevertheless, in relation to RCT data at least, all approaches that these reviewers used, when combined with a reconciliation process, yielded a high level of similar assessment decisions. Achieving a high level of consistency in assessing domains for observational studies is more problematic than for RCTs. However, even for these types of studies, the reconciliation process had a positive effect.

### Key Question 2. Principal Findings: Strength of Evidence Grades

#### Independent Reviewers

Agreement on independent reviewer strength of evidence grades overall was generally poorer than for domain scores. Across all 10 exercises, inter-rater reliability agreement for overall strength of evidence was slight. The level of agreement based on results from a subsample of four exercises that evaluated only evidence from RCTs was fair. Similarly, overall agreement in the GRADE study of RCT-only evidence had been fair.

When evidence was limited to RCT studies, better strength of evidence grades of moderate or high (compared with both insufficient and low) were related to RCT domain scores’ being considered consistent and precise. Because all RCT studies were presented as fair quality and were head-to-head trials, it is not surprising that the risk of bias and consistency domains were not predictors of the final strength of evidence grade.

The inclusion of observational studies, in addition to RCTs, in an exercise was a strong predictor of a poorer strength of evidence grade —namely, either insufficient or low versus moderate or high. Comments from reviewers seemed to indicate that they found the body of evidence to be more problematic to assess when these additional study designs were included. They expressed uncertainty concerning how to integrate findings from observational studies to support findings from RCTs.

Looking more closely at the relationship between specific observational studies domain scores and a strength of evidence grade of insufficient or low, we found that observational study evidence being considered low risk of bias was significantly related to strength of evidence being graded as insufficient (but not low) versus moderate or high. This counterintuitive finding may have been driven by the data in the two exercises with good-quality observational studies; the findings from these observational studies conflicted with the findings from the available RCT evidence. By considering the observational studies as well as the RCT data, reviewers might reasonably have concluded that they could not reach a conclusion about the body of evidence. Likewise, consistency of observational and RCT study findings was positively related to the strength of evidence grade being moderate or high versus insufficient. This finding would seem to reflect reviewers’ consideration of observational studies as secondary evidence that supports RCT evidence when the direction of the findings are clear and not in conflict with what was found through RCTs. In contrast, we were unable to find analogous patterns that would help explain strength of evidence grades of low versus moderate or high.

In relation to agreement on strength of evidence grades, we found that neither agreement on domain scores nor agreement about the level of difficulty that reviewers ascribed to evaluating particular domains predicted the overall grades. Even though reviewers expressed greater reservations in evaluating RA exercises (vs. MDD), differences in agreement were generally small and lacking informative patterns; for example, we saw greater agreement in domain scores for RA exercises and greater agreement in strength of evidence for MDD exercises. Differences in rates of agreement by type of outcome (benefits vs. harms) were also generally small and inconsistent.

We did not find that experience doing this kind of work resulted in consist decisions. Reviewers with greater experience in conducting systematic reviews (six of eight comparisons) and those with greater experience in evaluating strength of evidence (four of eight comparisons) were more likely to agree on domain scores. In contrast, reviewers with less experience (on both measures) were more likely to agree on strength of evidence grades than reviewers with greater experience.

We found few differences in agreement based on the type of academic training of reviewers (i.e., physician or nonphysician). The intent of this exercise was to distinguish any differences in results between reviewers who would be considered clinical experts and those who would be systematic review methodologists. Because all participants were experienced reviewers from EPCs and because we did not evaluate background knowledge of the particular clinical conditions, we concluded that this distinction likely did not capture differences among reviewers in clinical and methodological expertise.

Our data were insufficient to evaluate whether the methodological approach that reviewers used to arrive at an overall strength of evidence was related to agreement on the eventual grade.

#### Reviewer Pairs

Agreement on strength of evidence grades across reconciled pairs, compared with agreement for independent reviewers, improved modestly, from slight to fair, across exercises that had evidence from both RCTs and observational studies. It remained fair across exercises with only RCT evidence. Final strength of evidence grades that needed to be reconciled were no more likely to be changed to a better (higher) or a worse (lower) grade. We lacked sufficient data to determine whether the mechanism used to resolve disagreements between the two independent reviewers affected the final agreed-upon grade.

## Conclusions

This series of 10 exercises showed the level of diversity and complexity that EPC reviewers can encounter in their day-to-day evaluations. Our findings clearly demonstrate that the conclusions reached by experienced reviewers based on the same evidence can differ greatly. Of greatest concern is the poor level of agreement on the overall strength of evidence grades; these were typically notably lower than, and did not reflect agreement on, the domain scores from which they were intended to be derived. As presented in our analytic framework, we consider three factors that may have influenced the level of agreement on domain scores and final strength of evidence grades: reviewers’ methodological approach, their judgment, and training.

### Methodological Approach

By design, we included what we regarded as an “easy” exercise (Hamilton Rating Scale for Depression [HAM-D] response); it required evaluation of evidence based on meta-analysis results only from RCTs. Strength of evidence agreement for this exercise was substantial, and agreement for domain scores was high as well. This observation may indicate that the current guidance is sufficient for straightforward evaluations that can rely on quantitative tools for summarizing the available information.

In contrast, levels of agreement about overall strength of evidence across reviewers suffered when they were faced with qualitative evaluations; such groups of studies typically do not lend themselves to meta-analysis. Reviewers across EPCs used a variety of approaches that we could not clearly categorize as either methodological differences (i.e., different choice of criteria and instructions in making a decision) or judgment differences (i.e., insufficiently clear or gaps in guidance resulting in different interpretations of how to apply available guidance) and so our analysis could not distinguish which of these two categories was the likely cause of poor inter-rater reliability. Therefore, we discuss these additional concerns in relation to differences in judgment.

#### Judgment

Reviewers were uncertain and differed about how best to evaluate evidence that included a combination of studies with different approaches to measuring the same outcome construct. In this commonly faced problem, various measures may be considered similarly informative but differ across studies. For example, in the exercise concerning the MDD harm of sexual dysfunction, outcomes were measured as spontaneous events, abnormal ejaculation, libido decrease and different scale measures. Reviewers needed to judge how best to combine qualitatively all the data from studies with different outcome measures into domain scores.

In this example, reviewers’ decisions affected scoring of three key domains: consistency, directness, and precision. EPC guidance for this step in producing a CER may not be as helpful as is needed. For example, EPC guidance states that consistency can be scored based on the similarity of outcome measures, in addition to whether selected studies differ in direction and size of effects. It says that, for directness, some, but not necessarily all, measures may be direct. Finally, it notes that precision can be evaluated with respect to whether various measures point to a clinically useful conclusion. Because the original CER authors had determined that heterogeneous measures were appropriate for inclusion in the body of evidence to evaluate this one outcome, systematic review methodologists faced a complex set of decisions and their judgments differed.

Across reviewers, combining RCT and observational studies evidence into one final strength of evidence grade was problematic and not uniformly done. Guidance directs reviewers to assess separately the domain scores for RCTs and observational studies before combining them into a final grade, but it also supports reviewers’ discretion in how best to combine these separate assessments into a final grade. Reviewers can rely solely on the RCT evidence or incorporate the evidence from both RCTs and observational studies. Guidance is silent on how much weight to give observational studies relative to RCT data; in our exercises, reviewers differed in their decisions on this point.

Reviewers seemed reluctant to give a higher strength of evidence grade to findings that appeared to show no difference than to results that seemed to reflect some difference. Making this determination in these exercises was difficult because, in nine of these 10 exercises, reviewers could not rely on any quantitative assessment and because none of the exercises indicated clinically useful thresholds for precision.

To date, the EPC guidance about grading strength of evidence has reflected an orientation more toward “superiority” conclusions (and the confidence decisionmakers might have in one therapeutic option being truly better than another) than toward equivalence or “noninferiority.” Said another way, the guidance is more limited when effect sizes hover around the null (i.e., of no difference).

Curiously, even for specific domain scores and strength of evidence grading where agreement was slight or fair, reviewers were generally unlikely to consider designating the assessment task to have been either difficult or very difficult. This observation may indicate that reviewers did not appreciate the complexity of the evaluations, that they relied on different, ”personal” commonly used criteria for making their decisions, or that in fact they felt reasonably confident in their decisionmaking even if the exercises seemed complicated.

#### Training

Inadequate reviewer training likely led to some reductions in agreement in domain scoring. All reviewers were given the EPC strength of evidence guidance chapter and it should have been the primary resource for reviewers’ decisionmaking. In keeping with our goal of capturing current practice and expertise across EPCs, we did not provide reviewers with training on how to use and interpret the guidance in their evaluations. Based on reviewer comments, we believe that some reviewers did not follow clear directives in the guidance. This problem led to inappropriately considering some issues within incorrect domain categories; examples included addressing consistency concerns within risk of bias and addressing directness concerns within consistency. We saw obvious confusion about whether precision could be assessed in relation to one study, even though the guidance states that “not applicable” applies only to one study being included in assessing the consistency domain.

Experience in conducting reviews and evaluating strength of evidence translated into somewhat greater agreement on domain scores, which may reflect more experienced reviewers greater familiarity with the guidance and thus, making fewer of the mistakes listed above. However, their poorer consistency in overall strength of evidence grades, coupled with descriptions of the different approaches used across reviewer pairs, would seem to indicate that differences were not a result of inadequate training but differences in methodological approach and resulting judgments concerning how to combine scores into one final strength of evidence grade.

#### Study Limitations

Our findings and conclusions should be considered in light of several limitations. Because of concerns about introducing unmanageable complexity, we limited the assessment to the four “required” domains in the AHRQ EPC guidance. Thus, we did not allow reviewers to integrate findings based on dose-response association, plausible confounding, and strength of association (which are chiefly issues for observational studies and so could have aided in the integration of these studies) or publication bias.

We also required reviewers to evaluate evidence about two clinical conditions for which they may have had limited or no prior knowledge. Although we gave all reviewers background materials describing these conditions and know none worked on the original comparative effectiveness reviews, some reviewers may have had additional unmeasured prior knowledge whereas others may have been quite uninformed. We had no way of knowing who might have looked at any background materials and did not collect information that would have allowed us to control for level of knowledge in our analyses.

In addition, we had calculated and provided reviewers with p-values for exercises in which such information was missing from the original articles in the two CERs from which we took our basic information. We did not, however, calculate confidence intervals (when they were missing). Had we done so, such additional calculations might have improved agreement for, at least, the precision domain—a domain that clearly posed substantial challenges for these exercises.

Lastly, although we provided reviewers with detailed instructions on how to complete the exercises, we did not give them the criteria that the authors of the original CERs had applied to determine their own quality (or risk of bias) ratings of individual observational studies. Thus, reviewers might well have used different criteria or different scales to evaluate this particular attribute of included studies.

### Needed Guidance Enhancements and Future Research

#### Improved Guidance for Grading Strength of Evidence

Given these findings, we conclude that additional methodological guidance, including more detailed instruction, including examples and training, is needed for the EPC program. Such guidance needs to reflect various scenarios like the range of exercises we devised, which covered variations of “thornier” bodies of evidence that EPC reviewers face with virtually every evidence report they produce. Such expanded instructions may help reviewers rely less on their, potentially idiosyncratic, individual judgments concerning appropriate domain scores than in the past and should lay out in more detail the appropriate approach for summarizing these domain scores into a strength of evidence grade.

These challenges include (although are not limited to) all of the following circumstances:

- assessing consistency, precision, and directness when dealing with outcomes that investigators have assessed through more than one measure, such as we saw with sexual dysfunction;
- assessing precision, particularly when quantitative synthesis is not possible. Reviewers need greater guidance in how to establish imprecision based on clinical thresholds compared to imprecision that is due to studies that individually may have insufficient statistical power (particularly when evaluated through p-values rather than confidence intervals);
- assessing directness when evidence for an outcome includes both intermediate and final health outcomes and may also include indirect and head-to-head comparisons;
- evaluating strength of evidence for an outcome (either benefits or harms) that requires a qualitative synthesis of the evidence, particularly if it includes a combination of RCTs and observational studies, including the relative weight to give to the different study designs and how to combine the evidence when it does not point to similar conclusions;
- scenarios when it would be appropriate to grade a body of evidence other than “insufficient” when it includes all or some study findings that are not statistically significant but the studies were not designed to be equivalence or non-inferiority trials.

We were able to provide some insights into the reasoning behind strength of evidence grades of insufficient versus moderate/high, when outcomes are being evaluated through a combination of RCTs and observational studies. However, we were unable to explain the reasoning behind reviewers’ determinations of insufficient versus low strength of evidence grades, but we know that making this distinction can pose considerable challenges for those making such determinations. Thus, additional guidance will be helpful in this area as well. This is particularly true for situations in which outcomes are being evaluated through a combination of RCTs and observational studies.

Furthermore, we think that additional training for EPCs may be needed, certainly for newer or junior personnel in relation to both assessing domains and combining scores into strength of evidence grades. For example, reviewers may benefit from training in determining the appropriate domain to use to evaluate concerns (e.g., we observed at least one reviewer evaluate a consistency concern in their risk of bias assessment and overlap between consistency and precision assessments).

Reviewers bring to an evaluation varying levels of experience in making these decisions. More experienced reviewers may have strong personal preferences for how best to summarize the evidence into strength of evidence grades, based on interpretations developed by their EPC and other affiliations and they were more likely than less experienced reviewers to reach different conclusions. For these reviewers, discussions facilitated through examples, may help distinguish between differences resulting from methodology and judgment across EPCs and provide insights into where additional explanations for the reader, as well as guidance and related materials for reviewers may be needed. More detailed instructions, more use of interactive educational modules (or practice runs), and better explanations in AHRQ guidance of the rationale for arriving at different domain scores or strength of evidence grades may all be helpful.

Finally, these results raise a significant issue for transparency of EPC and AHRQ procedures. Although different approaches to this assessment task may all have validity, stakeholders need to be confident that different teams, confronted with the same evidence, would reach similar conclusions. If reviewers would apparently not reach similar grades or interpretations of that evidence, stakeholders would presumably like to know why this would happen. Improving the consistency of ultimate conclusions about evidence across EPCs (and also within EPCs) can be addressed only with consistent application of methods guidance. Related requirements and/or formats for clear explanation and documentation of how EPC review teams resolved complex decision points may be helpful. This in turn underscores our call for expanded and improved guidance about key steps, such as those noted above, for this important part of the systematic review process.

#### Future Research

Future research is needed to gain additional insights into reviewers’ rationales for differences in domain scores and strength of evidence decisions; our study provided only a first approximation for the reasons reviewers did what they did. Additional investigations could aim to distinguish more thoroughly than we could various reasons for differences, different approaches across EPCs resulting from gaps in guidance that should be filled, areas of insufficient understanding of the guidance itself and how best to overcome that deficit, and complex decisions that may still need to be left to the review team’s substantive expertise. We had limited our research to asking reviewers to explain their decisions when they had found an assessment difficult or very difficult; because relatively few indicated that this was their experience, we ended up with detailed feedback from only a small percentage of participants at several decision points.

Future reliability studies could be helpful, particularly, if they require step-by-step explanations for reviewers decisions. Testing reviewers’ consistency in incorporating “additional” domains (dose-response, confounding, and strength of association), particularly when bodies of evidence include observational studies, could help to provide greater guidance and related instructional materials concerning when and how to incorporate these domains. A study could also compare whether a more standardized approach to grading strength of evidence, such as GRADE, particularly arriving at an overall grade from domain scores, would provide greater reliability than the varied approaches that EPCs have been permitted to use in the current guidance. Such work should build on the types of scenarios we tested here; of particular concern are situations when reviews include heterogeneous outcomes that do not lend themselves to statistical summarization through meta-analysis and when evidence stems from a combination of RCTs and observational studies. If inter-rater reliability is similar when methods are constrained to stipulated approaches that are less discretionary than is the case now, then such findings might indicate not only that gaps remain in both approaches but also that, for complex evaluations, no “right” approach may exist. That, in turn, highlights the importance of transparency in methodology and findings and the need for adequate documentation and explanation that speaks to the needs of all stakeholders.