# Instructions Provided to Reviewers To Complete the Exercises

We provided participants with instructions and materials. The following documents were deemed essential materials for raters:

- Instructions for SOE reliability testing project (included in this Appendix)
- the chapter of the Methods Guide on grading the strength of a body of evidence2
- Background on SOE reliability testing project (included in this Appendix)
- Background on pharmacologic treatment for major depressive disorder
- Background on pharmacologic treatment for rheumatoid arthritis
  Summary table for each of the 10 grading exercises

We instructed participants to read a two-page background document that provided our project goals and approach along with a brief explanation of necessary versus supplemental information. The background document explained to participants that:

The project follows official guidance from AHRQ = which leaves some aspects of grading open to individual EPCs. We want to accommodate that flexibility = but we also want you to adhere to what is specified through the guidance presented in Owens (2010). Therefore = we are asking you to evaluate the four required domains for each outcome. In addition = we request that you provide separate domain scores for observational studies and RCTs. (Not all outcomes include observational studies. You will be prompted to answer accordingly for those that do.) However = we do not dictate the approach that you use to reconcile the conclusions of the two reviewers (domain scores and overall SOE grade) or the method to determine the final SOE grade for an outcome.

We designed the exercise so that participants could ideally answer all questions by reading the background information and using the summary tables. We advised reviewers to try this approach first. If reviewers found that they wanted more information to complete the exercise = we instructed them to then consult the supplemental materials—evidence tables and full text articles—that were provided in an attached zip file.

The supplemental materials provided far more information than reviewers needed but gave them the option of looking through source documents if they so choose. In case we inadvertently overlooked including information in summary tables that individual reviewers viewed as essential based on their typical process for grading SOE = we provided full evidence tables. We also provided the full articles.

#2 INSTRUCTIONS FOR STRENGTH OF EVIDENCE RELIABILITY TESTING PROJECT

### Stage I—Individual, independent grading

1. Read through this document (document name: #2-Instructions for strength of evidence reliability testing project); you may want to print it for easy reference as your work through the exercise.
2. Read the background document describing our overall project (document name: #3_Background on SOE reliability testing project).
3. Choose the condition (depression or rheumatoid arthritis) you’ll address first. Read the background document for the chosen condition (#4_Background on pharmacologic treatment for major depressive disorder) OR (#5_Background on pharmacologic treatment for rheumatoid arthritis).
4. Review the document that provides the 10 outcomes you will grade for our project (document name: SOE outcomes & corresponding summary tables). We recommend printing this document for easy reference to the pertinent data needed to grade all outcomes. The document is divided into two sections:
  a. Antidepressants—outcomes 1–5
  b. Arthritis drugs—outcomes 6–10
5. Choose the outcome with which you would like to begin. You are not required to address the outcomes in a particular order. However, we recommend that you complete all five outcomes for one condition before moving on to the outcomes for the other condition.
6. Open the document that contains links (URLs) to the online sites for recording your responses (document name: #7_Electronic response form links).
7. Select the appropriate link from the table (or copy and paste the URL into your web browser) to open up the Electronic Response Form for the outcome you would like to complete first.
  a. Internet access is required to complete the Electronic Response Form
  b. For each outcome, you will need to answer the questions in the order in which they are presented.
  c. You can use the BACK button on your internet browser to go back and view completed questions while inside the Electronic Response Form.
8. At the beginning of each Electronic Response Form link, you will be prompted to type in your name. The Electronic Response Form continues with prompts for you to enter the score for each required domain (separately for RCTs and observational studies, where relevant) and the overall strength of evidence grade for the outcome. Additionally, you will be prompted to assess the difficulty encountered in scoring individual domains and overall SOE grades. Some questions offer a drop-down menu of responses; others are open-ended, offering open text boxes for you to provide spontaneous responses/assessments. You will be prompted when a text box response is required.
  a. If at any point during the completion of the Electronic Response Form you would like to take a break, select the “Save for Later Completion” button at the bottom of the screen. This will take you back to the survey you were completing. You will be taken to the first page of the survey and will need to move forward through the survey to the point at which you quit. You will notice that your previous responses have been stored.
9. At the conclusion of each Electronic Response Form, select SUBMIT to submit your responses and then close the web browser window to exit.
10. Proceed to another outcome.
11. Repeat process just described (steps 7–10).
12. While all responses are recorded/submitted electronically, you may want to keep track of your domain scores and overall SOE grades. We have provided a document (document title: #8_Personal worksheet for SOE grading).
  a. We recommend that you print this document. You may want to complete it by hand as you grade the 10 outcomes. You are not required to do so.
  b. RTI will send you a spreadsheet with your domain scores and overall SOE grades for all outcomes within 5 days of your completion of the exercise. The personal worksheet is only needed if you wish to see your grades across outcomes as you complete the exercise.
13. To return to a completed survey to view questions and responses, simply click on the corresponding active link
14. This completes the first stage of the SOE reliability testing exercise.

Note: A glossary of abbreviations used in the summary tables and evidence tables is attached (document name: #9_Abbreviations). Evidence tables and full text articles of all studies included for each outcome are provided in the attached Zip files (MDD.zip AND RA.zip).

### Stage II—Paired reconciliation of scores/grades

1. Each person will be emailed a spreadsheet with the grades they submitted to RTI in Stage I.
2. Each partner group should go over each grade that they assigned and discuss any discrepancies.
3. One person in each pairing should use the Reconciliation Record document to keep track of all grades.
  a. The record should include grades that were agreed upon, as well as reconciled grades.
  b. Partner groups should take note of which domains were the most difficult, in order to report back later in the Electronic Response Form.
4. One person in each pairing will then use the Reconciliation Record document to fill out the Electronic Response Form for the Reconciliation Exercise.
  a. This form will ask for each grade to be entered and at the end, will also ask qualitative questions around the process of reconciliation.
5. To fill out the Electronic Response Form for the Reconciliation Exercise, select the link below to access the online form.
6. When prompted, fill in the name and EPC of each person in the reconciliation group.
7. Continue through the Electronic Response Form in the order the questions are presented, selecting grades from the drop-down menu and entering in responses to the qualitative questions in the text box provided.
  a. If at any time while filling out the Electronic Response Form you would like to take a break, simply select SAVE. When you re-click the link, you will be returned to that page of the online form.
8. At the end of the exercise, click SUBMIT to send the form to RTI. Close your browser window to exit.

#3 BACKGROUND ON STRENGTH OF EVIDENCE RELIABILITY TESTING PROJECT

### Project Goals

This project supports AHRQ’s efforts to provide guidance in methods for conducting systematic reviews (SRs) and comparative effectiveness reviews (CERs). We specifically focus on the step of grading the strength of a body of evidence (SOE). This step is described in a chapter of the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=328) and in the Owens et al.1 article (attached, document #10). The AHRQ education module on SOE is also available: http://www.effectivehealthcare.ahrq.gov/index.cfm/slides/?pageAction=displaySlides&tk=18.

AHRQ has a strong motivation to ensure a consistent understanding across EPCs in producing SRs and CERs; the Agency wants to promote transparency and clarity among outside stakeholders using the SRs and CERs. Thus, in designing this project, we identified several issues about SOE grading that warrant examination and created a dataset to gather empirical data from participating EPCs.

Our project focuses on reliability testing of the two main components of the task of grading SOE for specific outcomes in relation to key questions: (1) scoring evidence on the four required domains (risk of bias, consistency, directness, and precision) according to AHRQ’s latest guidance and (2) developing an overall SOE grade given the domain scores.

The project follows official guidance from AHRQ, which leaves some aspects of grading open to individual EPCs. We want to accommodate that flexibility, but we also want you to adhere to what is specified through the guidance presented in Owens (2010). Therefore, we are asking you to evaluate the four required domains for each outcome. In addition, we request that you provide separate domain scores for observational studies and RCTs. (Not all outcomes include observational studies. You will be prompted to answer accordingly for those that do.) However, we do not dictate the approach that you use to reconcile the conclusions of the two reviewers (domain scores and overall SOE grade) or the method to determine the final SOE grade for an outcome.

### Approach

We derived the materials for this project from two completed CERs: Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults;2 and Comparative Effectiveness of Second-generation Antidepressants in the Pharmacologic Treatment of Adult Depression.3 The evidence for the outcomes does not include all of the evidence included in the CERs. For our methods project, we included only a subset of the studies included in the CERs and only a subset of data from each study. Thus, the conclusions you reach will not necessarily mirror those from the CERs. No background knowledge of the comparative efficacy or harms of the drugs included in our exercise should play any role; rely solely on the evidence presented in the attached documents to determine the strength of evidence for each outcome. This is an exercise, not an actual CER. The sole goal of the project is to conduct a reliability test of the methods used to grade SOE.

For major depressive disorder, the drug comparison of interest is fluoxetine and paroxetine. For rheumatoid arthritis, the drug comparison of interest is between drug classes: biologics compared with oral DMARDs. The individual drug within a class should not factor into your evaluation—for the exercise, treat any individual biologic as DRUG 1 and treat any oral DMARD as DRUG 2.

A number of the included studies in our dataset include treatment arms that are not presented in the summary tables or evidence tables. Results for these arms should be disregarded. Please focus on the comparisons we have provided.

Necessary versus supplemental information: Do not be overwhelmed by the number of documents we have provided! We designed the exercise so that you could ideally answer all questions by first reading the background information and then using the summary tables. Try this process first and see if it suffices. If it does not, then turn to the supplemental materials—evidence tables and full text articles (provided in the attached “supplemental” zip files). We believe that we have provided far more information than you need, but you have the option of looking through source documents if you choose. We may have inadvertently overlooked including information in summary tables that you view as essential based on your typical process for grading SOE. Such information should be available to you in the evidence tables. We also provide the full articles to make available to you all relevant information. Please let us know if any tasks appear unduly burdensome or unclear before spending a lot of time trying to figure things out for yourself.

## References

1 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2009. Jul. 10.
2 Donahue KE, Gartlehner G, Jonas DE, et al. 2007. Comparative effectiveness of drug therapy for rheumatoid arthritis and psoriatic arthritis in adults. AHRQ Publication No.08-EHC004-1. Rockville, MD. Agency for Healthcare Research and Quality.
3 Gartlehner G, Hansen RA, Thieda P, et al. 2007. Comparative effectiveness of second-generation antidepressants in the pharmacologic treatment of adult depression, Comparative Effectiveness Review No. 7. (Prepared by RTI-UNC.). Rockville, MD. Agency for Healthcare Research and Quality.