# Strength of Evidence Summary Tables Used To Complete the Exercises

## ANTIDEPRESSANTS: FLUOXETINE VS. PAROXETINE

1 Benefits: HAM-D Response: Key Question: For adults with MDD, do commonly used medications for depression differ in efficacy or effectiveness in treating depressive symptoms?

5 RCTs/TOTAL N=690
Study | N | Quality | HAM-D Responders: Fluoxetine vs. Paroxetine
De Wilde 1993^9^ RCT | 100 | Fair | 63% vs. 68% (p=NS)
Gagiano 1993^12^ RCT | 90 | Fair | 63% vs. 70% (p=NR)
Fava 1998^10^ RCT | 109 | Fair | 57% vs. 58% (p=NS)
Chouinard 1999^8^ RCT | 203 | Fair | 68% vs. 67% (p=0.93)
Fava 2002^11^ RCT | 188 | Fair | 65% vs. 69% (p=NS)

Abbreviations: NR = not reported; NS = not sufficient; RCT = randomized controlled trial = vs. = versus.

For this exercise, we also provide the pooled data analysis (forest plot below).

Relative risk meta-analysis of response rates comparing fluoxetine with paroxetine on the HAM-D

[underlined: Heterogeneity (Non-combinability) of studies]

Cochran Q=0.668662 (df=4) p=0.9551

Moment-based estimate of between studies variance=0

I^2^ (inconsistency)=0% (95% CI, 0% to 64.1%)

[underlined: Random effects (DerSimonian-Laird)]

Pooled relative risk=1.031184 (95% CI, 0.918078 to 1.158226)

Chi^2^ (test relative risk differs from 1)=0.268365 (df=1) p=0.6044

This figure presents a plot of a random effects meta-analysis of the five randomized controlled trials included as evidence of the comparative benefit of fluoxetine versus paroxetine in relation to the outcome HAM-D. The relative risk of each of the studies is as follows: • Chouinard et al., 1999: 0.99 (95% CI: 0.81, 1.21) • De Wilde et al., 1993: 0.96 (95% CI: 0.65, 1.42) • Gagiano, 1993: 1.11 (95% CI: 0.81, 1.54) • Fava et al., 1998: 1.01 (95% CI: 0.73, 1.41) • Fava et al., 2002: 1.08 (95% CI: 0.87, 1.34) The combined relative risk is: 1.03 (95% CI: 0.92, 1.16), Heterogeneity (Non-combinability) of studies, Cochran Q=0.668662 (df=4) p=0.9551, Moment-based estimate of between studies variance=0, I² (inconsistency)=0% (95% CI, 0% to 64.1%), Random effects (DerSimonian-Laird), Pooled relative risk=1.031184 (95% CI, 0.918078 to 1.158226), Chi² (test relative risk differs from 1)=0.268365 (df=1) p=0.6044

2 Benefits: Response in elderly subpopulation Key Question: How does the efficacy of treatment with antidepressants differ in elderly or very elderly patients with MDD?

1 RCT/TOTAL N=108
Study | N | Quality | Results: Fluoxetine vs. Paroxetine
Schöne 1993^13^ RCT | 108 | Fair | HAM-D: Significantly more paroxetine responders (Results reported in bar graph only; p=0.03) MADRS: Significantly more paroxetine responders (Results reported in bar graph only; p=0.04)

Abbreviations: HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery Asberg Depression Rating Scale; RCT = randomized controlled trial.

3 Harms: Sexual dysfunction: Key Question: For adults with MDD, do commonly used antidepressants differ in the occurrence of the adverse event sexual dysfunction?

4 RCTs/TOTAL N=904
2 observational studies/TOTAL N=3,154
Study | N | Quality | Results: Fluoxetine vs. Paroxetine
Fava 1998^10^ RCT | 109 | Fair | Rate of spontaneously reported sexual dysfunction events (not explicitly defined);7% vs. 25%; (p=0.01^†^)
Chouinard 1999^8^ RCT | 203 | Fair | Abnormal ejaculation: 12.2% vs. 24.3%; (p=0.16^†^) Impotence: 7.3% vs. 10.8%; (p=0.59^†^)
Fava 2002^11^ RCT | 188 | Fair | Libido decrease: 14% vs. 15.6%; (p=0.77^†^) Abnormal ejaculation (corrected for gender): 11.8% vs. 20%; (p=0.34^†^)
Kroenke 2001^14^ Open-label RCT | 404 | Fair | Sexual function (based on 4 individual items constituting sexual functioning scale: sexual satisfaction, ED or inadequate lubrication, difficulty having orgasm, and ability to satisfy sexual partner)—difference between groups (p=NS)
Montejo 2001^16^ Prospective cohort study | 487 | Fair | Incidence of sexual dysfunction (assessed by Psychotropic-Related Sexual Dysfunction Questionnaire): 57.7% vs. 70.7%; (p=0.003^†^) Observed frequency of sexual dysfunction: Decreased libido: 50.2 vs. 63.9; (p=0.003^†^) Delayed orgasm/ejaculation: 49.5 vs. 63.9; (p=0.002^†^) Anorgasmia/no ejaculation: 39.1 vs. 52.8; (p=0.002^†^) Erectile dysfunction/decreased vaginal lubrication: 21.8 vs. 41.4; (p<0.0001^†^)
Clayton 2002^15^ Cross-sectional survey | 2,667 | Fair | Odds of sexual dysfunction by antidepressant taken (reference drug is bupropion SR): Fluoxetine: OR, 2.23; 95% CI, 1.75 to 2.87 Paroxetine: 2.89 (95% CI, 2.24 to 3.73) Prevalence of sexual dysfunction based on CSFQ total scores lower in FLUOX-treated patients; difference reached statistical significance

† p-value calculated post-hoc by RTI.

Abbreviations: CI = confidence interval; CSFQ = Changes in Sexual Functioning Questionnaire; ED = erectile dysfunction; FLUOX = fluoxetine; NS = not sufficient; OR = odds ratio; RCT = randomized controlled trial = SR = slow release; vs. versus.

4 Harms: Suicidality Key Question: For adults with MDD, do commonly used antidepressants differ in the occurrence of the adverse event suicidality?

1 RCT/TOTAL N=90
2 observational studies/TOTAL N=11,350
Study | N | Quality | Results: Fluoxetine vs. Paroxetine
Gagiano 1993^12^ RCT | 90 | Fair | Suicidal ideation (HAM-D item 3) score increase: Fluoxetine: 6 (13.3%) Paroxetine: 0 (p=0.026^†^) Score decrease: Fluoxetine: 29 (64.4%) Paroxetine: 31 (70.5%) No patient attempted suicide
Jick 2004^17^ Case-control study | 1,299 nonfatal suicidal behavior cases and controls from cohort that were prescribed fluoxetine or paroxetine | Fair | Relation between fluoxetine or paroxetine and nonfatal suicidal behaviors OR (95% CI), comparing each with dothiepin as the reference group: Fluoxetine: 1.16 (95% CI, 0.91 to 1.50) [cases: 31.7%, controls: 28.5%] Paroxetine: 1.29 (95% CI, 0.97 to 1.70) [cases: 24.3%, controls: 19.4%]
Martinez 2005^18^ Nested case-control study | Cases and controls, nonfatal self harm: 10,051 Cases and controls, completed suicides312: | Good | Risk of non-fatal self harm in people prescribed fluoxetine (compared with paroxetine as reference): adjusted* OR, 0.94 (95% CI, 0.79 to 1.11) Risk of completed suicides in people prescribed fluoxetine (compared with paroxetine as reference): adjusted* OR, 0.42 (95% CI, 0.13 to 1.39) *Adjusted for severity of depression, time depression was diagnosed in relation to start of txt, referral to psychiatrist or psychologist before index day, history of self harm, diagnosis of or txt for anxiety or panic disorder, schizophrenia, antipsychotic drugs, drug misuse, and alcohol misuse

† p-value calculated post-hoc by RTI

5 Harms: Nausea Key Question: For adults with MDD, do commonly used antidepressants differ in the occurrence of the adverse event nausea?

6 RCTs/TOTAL N=689
Study | N^*^ | Quality | Results: Fluoxetine vs. Paroxetine
De Wilde 1993^9^ RCT | 100 | Fair | 20% vs. 20.4% (p=NS)
Gagiano 1993^12^ RCT | 90 | Fair | 33.3% vs. 36.4% (p=0.764^†^)
Schöne 1993^13^ RCT | 108 | Fair | 11.5% vs. 9.3% (p=0.701^†^)
Chouinard 1999^8^ RCT | 203 | Fair | 31.7% vs. 37.3% (p=0.404^†^)
Fava 2002^11^ RCT | 188 | Fair | 15.2% vs. 25.0% (p=0.095^†^)

* N=total fluoxetine and paroxetine patients only

† p-value calculated post-hoc by RTI

## ARTHRITIS DRUGS: BIOLOGICS VS. ORAL DMARDS

6 Benefits: ACR20 Response Key Question: For patients with RA, do drug therapies differ in their ability to reduce patient-reported symptoms, to slow or limit progression of radiographic joint damage, or to maintain remission?

5 RCTs/TOTAL N=1,639
2 observational studies/TOTAL N=2,461
Study/Design | N | Comparison | Quality | Results: Biologics vs. Oral DMARDs
ERA study, 2000^19,24^ RCT | 424 | ETN 25 mg twice/wk vs. MTX (mean 19mg/wk) | Fair | At 12 months: 72% vs. 65%, (p=0.16)
Edwards 2004^22^ RCT | 80 | RTX vs. MTX | Fair | 24 weeks: 65% vs. 38%; (p=0.025) 48 weeks: 33% vs. 20%; (p=0.204^†^)
TEMPO, 2005^25–27^ RCT | 451 | ETN 25 mg twice/wk vs. MTX | Fair | At 52 weeks: 76% vs. 75%; (p=NS)
Combe 2006^21^ RCT | 153 | ETN 25 mg twice/wk vs. SSZ | Fair | At 24 weeks: 73.8% vs. 28.0%, (p<0.01)
PREMIER, 2006^20^ RCT | 531 | ADA 40 mg biweekly vs. MTX 20 mg/wk | Fair | Year 1: 54% vs. 63%, (p=0.043)
Geborek 2002^28^ Nonrandomized open-label trial (Effectiveness trial) | 269 | ETN 25 mg twice/wk vs. LEF | Fair | Greater ACR20/50 responses for ETN at 3 months (p<0.001) and 6 months (p<0.05) [data reported in bar graph only]
Weaver 2006^29^ Prospective cohort study | 2192 | ETN vs. MTX | Fair | ETN patients significantly more likely to achieve ‡mACR20 response at 12 months: adjusted* OR, 1.23 (95% CI, 1.02 to 1.47); (p<0.05) *adjusted for baseline covariates: age, baseline HAQ score (>1.5 vs. ≤1.5), comorbid disease (presence vs. absence), physician’s judgment of disease severity, duration of RA, employment/disability status, Medicare coverage, race, sex, previous txt with DMARDs, previous txt with biologics, insurance status, and highest educational level attained

† p-value calculated post-hoc by RTI

‡ Excludes ESR/CRP criterion from ACR

Abbreviations: CI = confidence interval; DMARD = disease modifying antirheumatic drug; ETN = etanercept = HAQ = Health Assessment Questionnaire; mACR20 = Modified American College of Rheumatology; MTX = methotrexate; NS = not sufficient; OR = odds ratio; RA = rheumatoid arthritis; txt = treatment; vs. = versus.

7 Benefits: ACR70 Response Key Question: For patients with RA = do drug therapies differ in their ability to reduce patient-reported symptoms = to slow or limit progression of radiographic joint damage = or to maintain remission?

5 RCTs/TOTAL N=1 =639
1 observational study/TOTAL N=269
Study/Design | N | Comparison | Quality | Results: Biologics vs. Oral DMARDs
ERA Study = 2000^19,24^ RCT | 424 | ETN 25 mg twice/wk vs. MTX (mean 19mg/wk) | Fair | At 12 months: no significant differences between txt groups
Edwards 2004^22^ RCT | 80 | RTX vs. MTX | Fair | 24 weeks: 15% vs. 5%; (p=NS) 48 weeks: 10% vs. 0%; (p=NS)
TEMPO = 2005^23,25–27^ RCT | 451 | ETN 25 mg twice/wk vs. MTX | Fair | 52 weeks: 24% vs. 19%; (p=0.166^†^)
Combe 2006^21^ RCT | 153 | ETN 25 mg twice/wk vs. SSZ | Fair | 24 weeks: 21.4% vs. 2% = (p<0.01)
PREMIER = 2006^20^ RCT | 531 | ADA 40 mg biweekly vs. MTX 20 mg/wk | Fair | Year 1: 26% vs. 28% = (p=0.585^†^)
Geborek 2002^28^ Nonrandomized open-label trial (Effectiveness trial) | 269 | ETN 25 mg twice/wk vs. LEF | Fair | 12 months: differences between txt groups: (p=NS)

† p-value calculated post-hoc by RTI

Abbreviations: ETN = etanercept = LEF = lefluonomide; mg = milligram; MTX = methotrexate; NR: not reported; NS = not sufficient; RCT = randomized controlled trials; SSZ = sulfasalazine; txt = treatment; vs. = versus; wk = week.

8 Benefits: DAS Remission Key Question: For patients with RA = do drug therapies differ in their ability to reduce patient-reported symptoms = to slow or limit progression of radiographic joint damage = or to maintain remission?

2 RCTs/N=982
1 observational study/N=1 =083
Study/Design | N | Comparison | Quality | Results: Biologics vs. Oral DMARDs
TEMPO = 2005^23,25–27^ RCT | 451 | ETN 25 mg twice/wk vs. MTX | Fair | Remission at week 24: DAS<1.6: 13.0% vs. 13.6% (p=NS) DAS28<2.6: 13.9% vs. 13.6% (p=NS) Remission at week 52: DAS <1.6: 17.5% vs. 14% = (p=NS) DAS28<2.6: 17.5% vs. 17.1% = (p=NS)
PREMIER = 2006^20^ RCT | 531 | ADA 40 mg biweekly vs. MTX 20 mg/wk | Fair | Clinical remission (DAS28<2.6) at 1 year: 23% vs. 21% = (p=0.582^†^)
Listing 2006^30^ Prospective cohort study | 1083 | Biologics vs. conventional DMARDs | Fair | Odds of achieving remission (DAS28<2.6) at 12 months: Adjusted* OR = 1.95 (95% CI = 1.20 to 3.19); (p=0.006) *Adjusted for age = sex = # of previous DMARDs = DAS28 = ESR = FFbH = osteoporosis = previous txt with cyclosporine A. Matched pairs analysis^‡^ DAS28 remission at 12 months: 24.9% vs. 12.4% = (p=0.004)

† p-value calculated post-hoc by RTI

‡ Pairs of biologic and oral DMARD patients differing by less than 0.05 on propensity score

Abbreviations: ADA = adalimumab; CI = confidence interval; DAS = Disease Activity Score; DMARD = disease modifying antirheumatic drug; ESR = erythrocyte sedimentation rate; FFbH = Funktionsfragebogen Hannover Functional Status Questionnaire; ETN = etanercept; mg = milligram; MTX = methotrexate; OR = odds ratio; NS = not sufficient; RCT = randomized controlled trials; txt = treatment; vs. = versus; wk = week.

9 Harms: Serious Infections Key Question: For patients with RA = do drug therapies differ in harms = tolerability = adherence = or adverse effects?

4 RCTs/TOTAL N=1 =215
2 observational studies/TOTAL N=7 =695
Study/Design | N | Comparison | Quality | Results: Biologics vs. Oral DMARDs
Edwards 2004^22^ RCT | 80 | RTX vs. MTX | Fair | 2 patients (5%) vs. 1 patient (2.5%) (p=NR)
TEMPO = 2005^23,25–27^ RCT | 451 | ETN 25 mg twice/wk vs. MTX | Fair | 4% vs. 4% (p=NS)
Combe 2006^21^ RCT | 153 | ETN 25 mg twice/wk vs. SSZ | Fair | ETN: 3 serious infections in 2 patients SSZ: 0 serious infections (p=NS)
PREMIER = 2006^20^ RCT | 531 | ADA 40 mg biweekly vs. MTX 20 mg/wk | Fair | TEAEs -# of events per 100 patient-years Any serious infection: 0.7 vs. 1.6; (p=NS) TB: 0 vs. 0
Curtis 2007^31^ Retrospective cohort study | 5 =326 | Biologics vs. MTX | Fair | Serious infections during entire study period: 2.7% vs. 2.0%; number needed to harm=143 Crude HR (95% CI) biologic treatment association with hospitalization with a definite bacterial infection: HR = 1.39 (95% CI = 0.97 to 1.98) Adjusted* HR (95% CI) biologic treatment association with hospitalization with a definite bacterial infection: HR = 1.94 (95% CI = 1.32 to 2.83) *Adjusted for age = sex = U.S. region of residence = insurance status = comorbid diseases = corticosteroid use = MTX use
Schneeweiss 2007^32^ Retrospective cohort study | 2 =369 | Biologics vs. MTX | Good | Compared with MTX no higher rates of serious bacterial infections in elderly patients; adjusted* model: RR = 1.0 (95% CI = 0.6 to 1.71) *Adjusted for age = sex = race = nursing home residence = hospitalization = # of physician visits = # of distinct prescription drugs = Charlson comorbidity score = RA severity = independent predictors of serious infections = previous antibiotic use = influenza vaccination and pneumococcal vaccination.

Abbreviations: CI = confidence interval; ETN = etanercept; mg = milligram; HR = hazard ratio; MTX = methotrexate; NR = not reported; NS = not sufficient; RCT = randomized controlled trials; RA = rheumatoid arthritis; RTX = TB = tuberculosis; TEAE = treatment emergent adverse event; vs. = versus; wk. = week.

10 Harms: Infusion or Injection Reaction Key Question: For patients with RA = do drug therapies differ in harms = tolerability = adherence = or adverse effects?

4 RCTs/TOTAL N=1 =108
Study/Design | N | Comparison | Quality | Results: Biologics vs. Oral DMARDs
ERA = 2000^19,24^ RCT | 424 | ETN 25 mg twice/wk vs. MTX (mean 19mg/wk) | Fair | 37% vs. 7% (p<0.001)
Edwards 2004^22^ RCT | 80 | RTX vs. MTX | Fair | Any event associated with first infusion: 45% vs. 30% (p=0.166^†^)
TEMPO = 2005^23,25–27^ RCT | 451 | ETN 25 mg twice/wk vs. MTX | Fair | 21% vs. 2% (p<0.0001)
Combe 2006^21^ RCT | 153 | ETN vs. SSZ | Fair | 32.0% vs. 2.0% (p<0.05)

† p-value calculated post-hoc by RTI

Abbreviations: ETN = etanercept; MTX = methotrexate; RTX = Rituximab; SSZ = sulfasalazine; vs. = versus; wk = week