# Acknowledgments

The authors would like to acknowledge the following individuals who provided assistance during this project.

We thank two RTI International colleagues: Carla Bann, Ph.D., for statistical and psychometric consultation, and Loraine Monroe for technical word processing.

We are very indebted to the assistance from our inter-rater reliability reviewers:

Agency for Healthcare Research and Quality
- Suchitra Iyer, Ph.D.
- Elisabeth Kato, M.D., M.R.P.

University of Alberta EPC
- Donna Dryden, Ph.D.
- Lisa Hartling, M.Sc., Ph.D.

ECRI Institute EPC
- Meredith Noble, M.S.
- Jonathan Treadwell, Ph.D.

University of Minnesota EPC
- Mary Butler, Ph.D.
- Tatyana Shamliyan, M.D.

Oregon Health and Science University EPC
- Susan Norris, M.D., M.Sc., M.P.H.
- Kim Peterson, M.S.
- Shelley Selph, M.D., M.P.H.
- Marian McDonagh, Pharm.D.

University of Ottawa EPC
- Mohammed Ansari, M.B.B.S., M.Med.Sc., M.Phil.
- Alex Tsertsvadze, M.D., M.Sc.

RTI-University of North Carolina EPC
- Stacey Lloyd, M.P.H.
- Mike Trisolini, Ph.D.

Tufts University-New England Medical Center EPC
- Denish Moorthy, M.B.B.S., M.S.
- Winifred Yu, M.S., R.D.

Vanderbilt University EPC
- Jeff Andrews, M.D.
- Melissa McPheeters, Ph.D., M.P.H.

Southern California-Rand EPC
- Alicia Ruelaz, M.D.
- Zhen Wang, M.S.