# Results

The results are organized in three sections: What is Topic Refinement, Guiding Principles, and The Mechanics of Conducting a Topic Refinement. This third section combines a description of an aspect of the topic refinement process (e.g., initial topic refinement phase) with a discussion of various best practices and issues for investigators.

## What is Refinement?

Refinement implies making changes to attain a better fit with a certain standard. In this sense, the goal of topic refinement is to improve a nominated topic so that it is a good and accurate fit with a number of criteria (see Box 1). A well-refined topic accurately and precisely reflects the health care question or dilemma the systematic review is intended to address. It aligns with the priorities and values of a broad range of relevant stakeholders and users of the systematic review. It should accurately reflect the state of the science and technical aspects of the topic. It should be compatible with systematic review research methods.

Box 1 Criteria that a refined topic should fit

♦ The health care question or dilemma the systematic review aims to address
♦ The priorities and values of relevant stakeholders and users of the systematic review
♦ The state of the science and technical aspects of the topic
♦ Systematic review research methods

Nominated topics may be inadequately precise, overly inclusive, or overly narrow in their descriptions of the populations, interventions, comparators, and/or outcomes of interest. Hence, refinement of a topic for public health and/or clinical relevance and for research feasibility may involve narrowing the focus of some elements of the PICOTS, expanding some elements, or both. This process more closely resembles sculpting in clay than sculpting in marble.

Topic refinement investigators strive to optimize the fit of the topic with all of the categories in Box 1. To do so may require a balanced compromise that considers the relative importance and/or practicality of the criteria. For example, certain stakeholders might nominate a topic highly relevant for their own constituency but also very narrowly focused. A topic refinement investigator might recognize the potential for viably expanding the focus of such a topic to be more broadly relevant to other stakeholder groups, with little or no reduction in relevance to the nominating group. At the same time, the results of a literature scan might suggest that certain aspects of the question have already been adequately answered and therefore should not be included in a new review. Decisions that produce relevant and researchable (and therefore useful) Key Questions lie at the heart of the topic refinement process.

## Guiding Principles

In refining a topic, investigators make numerous decisions to include, exclude, or otherwise modify aspects of the populations, interventions, comparators, outcomes, and settings of interest. They also decide how these elements of the PICOTS should relate to one another as formulated in the Key Questions and analytic framework. Our reviews and discussion of previous topic refinements suggested that investigators variably consider and apply principles when making decisions and refinements; however, the basis upon which these decisions are made has not been previously formalized.

We identified seven guiding principles to be routinely and systematically considered in the course of refining a nominated topic for a systematic review (see Box 2). These are: (1) fidelity to the original nomination; (2) relevance; (3) research feasibility; (4) responsiveness to stakeholder input; (5) reducing investigator bias; (6) transparency, and (7) suitable scope. Four principles (fidelity, responsiveness, minimizing investigator bias, and transparency) relate primarily to the conduct of the topic refinement process, and three relate more to the topics themselves (relevance, research feasibility, and suitable scope). These inter-related principles for topic refinement are consistent with those previously described in the EPC guidance for conducting systematic reviews, including relevance, timeliness, objectivity, scientific rigor, public participation, transparency, and emphasis of a patient-centered perspective.11

Box 2 Guiding principles for topic refinement

♦ Fidelity to the original nomination retains the essential intent of the nominator and does not necessarily strive to satisfy the specific purpose of a given nominator. This assures that topics and systematic reviews are based on real-world issues that are important to stakeholders and that the systematic review will have relevance to a ready audience.
♦ Topics have relevance to those who would make decisions with the findings of the systematic review, as well as those who would be affected by those decisions.
♦ Research feasibility pertains to the practicality of conducting a review using systematic review methods within available resources.
♦ Responsiveness to stakeholder input assures that topics are tied to real-world concerns and decisional dilemmas, but does not require integration of all input.
♦ Each investigator brings their experience, expertise, perspective and values, which could introduce bias. Aspects of the topic refinement process can reduce possible investigator bias.
♦ Transparency in reporting includes a clear description of topic refinement decisions and the underlying rationale. This is important for public accountability and the integrity of the topic refinement process.
♦ A topic scope is the degree of inclusiveness reflected in the PICOTS, Key Questions and analytic framework. Defining a suitable scope for a topic requires the investigator to consider numerous factors that affect the complexity and level of detail of the Key Questions.

To satisfy a certain principle an investigator may have to compromise on satisfying another principle. For example, to increase the relevance of a nominated topic that specified a very limited population or setting an investigator might substantially broaden the scope of the PICOTS. In turn, this broader scope might reduce the feasibility of researching the topic. Given that topics vary widely, the relative importance of each principle may also vary according to the topic being refined. Hence, these recommendations are not meant to prescribe how these principles should be applied or balanced for individual topics, only that they be considered. Inevitably, skilled investigators will use their judgment and discretion in refining topics, often making trade-offs between various objectives. We envision investigators using the following seven guiding principles for more systematic and explicit decisionmaking.

### Fidelity to the Original Nomination

The EHC Program is committed to addressing patient-centered health care questions that are tied to the concerns and decisional dilemmas of a broad range of stakeholders—from patients to advocacy groups to professional societies. And while the program does not necessarily strive to satisfy the specific purposes of given nominators, maintaining fidelity to the original nomination assures that topics and systematic reviews are based on real-world issues that are important to stakeholders. Fidelity to the nomination also assures that the systematic review will have relevance to a ready audience. Topic refinement might change the PICOTS and with them the aims of the review. Investigators should be mindful of the initial intent of the nominator as they narrow or broaden a topic so that the resulting review can be useful to a broad range of stakeholders.

### Relevance

Topics should be relevant to decisional issues that matter to the users of the systematic review, and should include outcomes that matter to patients even when the evidence may be scarce.12 Some nominated topics of high relevance to the nominator may be too narrowly framed to be of great use to a broader audience. Thus, topic refinement investigators may broaden or change the scope of the topic to increase its relevance. For example, in the original nomination of a topic on the effectiveness of case management13 the nominator specified case management performed by certified nurse case managers. The literature scan and input from Key Informants suggested that case management is frequently conducted by nurses without special certification and by professionals other than nurses. Therefore, the topic was expanded to be more broadly inclusive and relevant to a wider variety of case managers (while maintaining fidelity to the original nomination).

The investigator refines the topic to reflect the underlying clinical logic, which includes the relevant clinical concepts and beliefs about the mechanism by which interventions may improve health outcomes9. This requires an understanding of the relative strengths and weaknesses of the arguments for (1) including particular populations, interventions, comparators, outcomes and settings, and (2) the proposed relationships between these elements. This understanding should be reflected in the analytic framework and Key Questions. A topic might be generally relevant for a particular issue or audience, but its relevance is limited if the details of the formulated analytic framework and Key Questions do not reflect the intrinsic clinical logic of the topic. For example, the original nomination for a topic on the treatment of pressure ulcers14 included as an outcome the progression of an ulcer to a more advanced stage. Key Informants emphasized that traditional staging systems imply a natural progression in wound severity that ignores variability in etiology. They also emphasized that progression of stage may not always be a relevant outcome. Therefore, the refined topic did not include progression of stage as an explicit outcome of interest.

### Research Feasibility

Research feasibility pertains to the practicality of conducting a review using systematic review methods within a specified timeframe and budget. Factors that affect research feasibility are the complexity of the health care issue of interest; the clarity and precision of the Key Questions; the relative heterogeneity of the PICOTS elements; the scope of the topic; and the size and nature of the evidence base.

Key questions that explicitly address the clinical logic and complex aspects of a topic enhance the feasibility and improve the usefulness of the systematic review. For example, a topic was originally nominated in very general terms as “Can screening and surveillance for colorectal cancer using fecal DNA analysis improve health outcomes?”15 As nominated, this topic did not reflect the underlying complexity of the issue. To make the clinical logic of the topic explicit, the team included Key Questions and an analytic framework that addressed test characteristics, test performance compared with established screening methods, acceptability and adherence to testing, optimal screening intervals, impact on patient-centered outcomes, and harms. Making these important aspects of the topic explicit enhanced its research feasibility.

The clarity and precision of the Key Questions and PICOTS directly influence systematic review inclusion and exclusion criteria. Questions that are unclear or vague may be cumbersome or too complex to answer. Precise Key Questions allow for clearer decisions about the evidence and its synthesis, producing more accurate and efficient reviews. Similarly, the heterogeneity of the PICOTS may also affect research feasibility. A topic that includes diverse populations, interventions, outcomes and/or settings may be more cumbersome to research. A heterogeneous mix of PICOTS and Key Questions may make evidence synthesis more complicated and presentation of the findings less clear.

The scope of a topic may also affect research feasibility. If a topic addresses numerous health care issues, or aspects of an issue, the synthesis of the evidence and communication of findings may be challenging. The topic refinement team may have to decide whether to conduct one systematic review should include them all or multiple more narrowly focused reviews. Such decisions should consider whether a high degree of inclusiveness would allow for clear and precise Key Questions, and whether a lower degree of inclusiveness would reduce relevance for decisionmaking.

Closely related is the influence of the evidence base. If the evidence base is large, it may be unwieldy and impractical to extract and synthesize the relevant literature within available resources. This might suggest the need to split the topic into multiple reviews, or to further focus and narrow the Key Questions. Investigators should consider whether such refinements would reduce the relevance of the review. Conversely, a small evidence base does not necessarily imply that the topic is not feasibly researchable. If certain questions are deemed highly relevant for important decisional dilemmas, then characterizing the evidence base—even if it is lacking—may be useful. Other aspects of the evidence base may also affect research feasibility, such as the design and quality of included studies.

As an example, an original nomination that included both screening for hepatitis C virus (a population health question) and treatment of hepatitis C virus (an individual health question) was refined and divided into two separate systematic reviews due to complexity of the Key Questions, volume of literature, and timeliness of review.16,17 Key Informants emphasized the importance of understanding treatment effects, and inclusion of new treatment regimens and testing options. The Key Questions were revised to capture the complexities raised by Key Informants, and significantly expanded the scope of the review. To feasibly and adequately review the literature in a timely fashion at the level of detail emphasized by stakeholders, two separate reviews were developed in tandem.

### Responsiveness to Stakeholder Input

To assure that topics are tied to real-world concerns and decisional dilemmas, the topic refinement team is responsive to the input of stakeholders, including those making public comments. Key Informants may differ in their perspectives, understanding, values, and priorities about the health care issues. It is not a goal of topic refinement to reach consensus among stakeholders. Consensus may arise spontaneously, suggesting that the PICOTS and Key Questions are on target. However, a lack of consensus may be equally useful in highlighting an area of disagreement that the team may further explore before making a refinement decision.

By considering the viewpoints and priorities of a broad range of stakeholders, the team may reduce the potential bias of singular views and avoid investigator tunnel vision. This does not imply, however, that the topic refinement team must comply with or incorporate all stakeholder input. Stakeholders can provide the investigators with a diversity of perspectives to consider, but the ultimate topic refinement decisions belong to the topic refinement team.

### Reducing Investigator Bias

A topic refinement investigator serves as an arbiter who weighs and integrates information and viewpoints from various sources (literature, topical experts, and Key Informants). Each investigator also brings their experience, expertise, perspective, and values, which could bias the process. Numerous aspects of the topic refinement process can reduce the possible effect of investigator bias. First, as a deliberative process among members of a team, the assumptions and viewpoints of investigators can be made explicit and discussed. In this way, the team can become aware of their possible biases. This awareness allows them to more easily consider their views in relation to other input garnered during topic refinement. The deliberative nature of the process also facilitates the explicit consideration of possibly conflicting views of experts and/or stakeholders. Second, the EHC Program enforces a conflict of interest policy for investigators.18 Third, a topic refinement team considers input from diverse stakeholders whose viewpoints and priorities may challenge the assumptions of investigators, identify gaps or inconsistencies in thinking, and provide insight into different values related to the questions of interest. Finally, topic refinement is a structured process that formalizes the steps of gathering and processing information, making refinement decisions, and transparently reporting those decisions. The consistency and structure of the process can help to assure that topic refinement investigators openly and judiciously consider various relevant viewpoints, including those that are new or different than their own.

### Transparency

The evidence that influenced crucial topic refinement decisions and the rationale underlying critical refinements should be clearly and explicitly described and documented. This principle is important for public accountability, scientific rigor, and efficiency in the subsequent steps of conducting the systematic review.

Whitlock et al.5 described public accountability as an ethical requirement for topic identification and selection in the EHC Program, because EHC decisions affect the allocation of limited public resources for comparative effectiveness research. The same principle and rationale apply to the topic refinement process. Stakeholders will have different perspectives and priorities regarding a given topic. Interested parties should be able to determine if and how their priorities were considered in the topic refinement process. Not all stakeholder input will necessarily have been included in the topic refinement process, but transparency allows for public accountability.

Transparency in reporting can also provide important insight into how the research process affected the outcome. The unavoidable subjectivity in the topic refinement process precludes its replication as in a controlled experiment. Yet, this same element of subjectivity makes transparent reporting all the more desirable for a rigorous process. The judgment and discretion of individual investigators will always come into play. This implies that two investigators or topic refinement teams presented with the same original topic nomination could make different decisions and refinements and thereby produce two topics with different PICOTS and Key Questions from a single original topic. Documenting the influence of specific assumptions, evidence, stakeholder input, and rationales allows a critical reviewer or a stakeholder to understand the basis upon which particular refinements to the topic were made.

Transparent documentation of the topic refinement process can also be of value in the subsequent stages of the systematic review. A clear record of the topic's evolution that describes the factors and thinking behind refinements can improve the efficiency and coherence of the systematic review process. This helps to prevent unnecessary duplication of effort on previously addressed questions while providing background context in light of which new questions can be considered.

Summary reports from different EPCs have displayed considerable variability in the detail and transparency of documentation. To make these reports more reliably transparent, we recommended changes to the Topic Refinement Document, including more explicit instructions and a structured guide for more complete reporting of the evolution of the topic. These changes have been incorporated into an updated document (Appendix A) and are described in the section on “Reporting,” below.

### Suitable Scope

The scope of a topic refers to its relative degree of inclusiveness as reflected in the PICOTS, Key Questions, and analytic framework. The designated scope of a topic is related to a variety of factors, including the topic's intended relevance and research feasibility. A topic of narrow scope might be restricted to a single form of an intervention in a particular subpopulation with one outcome of interest and a single setting; it may lack the most relevance. In contrast, a topic of broad scope might include various forms of the intervention in the general population and include multiple outcomes and settings; it may present challenges for research feasibility. A suitable scope is sufficiently inclusive to have high relevance and usefulness for decisionmakers, and yet is not so broad as to reduce the coherence of the review and the precision of its findings.

The scope may also vary according to the complexity of the PICOTS elements and their interrelationships as expressed in the Key Questions. For example, a topic on the use of disease-modifying antirheumatic drugs (DMARDs) for treatment of juvenile idiopathic arthritis (JIA)19 included multiple types of DMARD and multiple subtypes of JIA. In addition to the breadth of scope directly related to including numerous interventions (DMARDs) and numerous subpopulations (JIA subtypes), the scope of the topic was further broadened to include the question of variable effectiveness of different DMARDs with different JIA subtypes.

The scope of a topic may also be a function of the level of detail in the Key Questions. In general, higher specificity and detail in the PICOTS and Key Questions will constrain the focus of the topic and limit its scope. That is not to say that a topic with highly detailed Key Questions is always of narrow scope, as a topic of broad scope by virtue of addressing numerous issues with many Key Questions might have a high level of detail in those questions. Scope is distinct from the other principles, in that a description of the suitable scope is a goal of topic refinement and not a principle, per se. However, refinement decisions must usually consider scope in much the same way as the other principles.

### Other Programmatic Considerations

The three major stages of a topic in the EPC program (topic nomination and development, topic refinement, and systematic review) are guided by separate but complementary criteria and principles. Infrequently, the topic refinement team may discover (perhaps through input from Key Informants or a more detailed literature scan) that that the topic as proposed no longer fulfills the program's selection criteria. Even though the considerations and purposes of topic development and topic refinement are separate and distinct, a topic in the refinement period must still fulfill the original selection criteria. If the topic cannot be reframed to fulfill the selection criteria it may not proceed to a systematic review.

Similarly the topic refinement team is mindful of the principles for the conduct of the systematic review. The application of topic refinement guiding principles can facilitate the principles for the conduct of the systematic review. Exercising the principles of responsiveness and relevance can promote a patient-centered approach to the evidence. The engagement of relevant stakeholders can elucidate the clinical logic. For example, during the topic refinement process for point-of-care testing for hemoglobin A1c (HbA1c), the topic refinement team learned that another systematic review on the same topic was underway.20 The Key Informants felt that it answered their questions; it was the decision by the team and AHRQ that a new systematic review on this topic would be duplicative and would not add to the current body of knowledge.

In another example, the topic refinement team for enzyme replacement therapy for lysosomal storage disease21 discovered that evidence was limited for the relevant outcomes for this rare condition. The team weighed several factors in addition to the small body of evidence on long-term effectiveness and harms, such as the inclusion of many study types (small trials, case series, and case reports) and the high potential for impact (affirmed by the absence of systematic reviews and by the Key Informants). Considering these factors, the team proceeded with a different type of EPC report, a technology brief, rather than a systematic review. The alternative report was more appropriate for the volume of the literature and the state of the science, while still providing information that would be relevant, timely, and useful for decisionmakers.

## The Mechanics of Conducting a Topic Refinement

During topic refinement in the EHC Program, nominated topics are ushered through several phases (Figure 2). Although the essential phases of the process follow a logical temporal sequence, the resulting changes in the topic may not always flow in a linear and predictable way. The outcome of one phase (e.g., Key Informant interviews) may lead to a revision in the outcome of a previous phase (e.g., Key Questions developed in the initial topic refinement). Certain aspects of the topic will fall into place before others, in no set order. Furthermore, the details of how a given phase of the process is conducted will differ depending on the nature and requirements of the particular topic; the skills, expertise, and experience of the topic refinement team; the particular Key Informants; and the resources of the individual EPC. Investigators must apply judgment and discretion when planning and conducting the various phases of the process.

The degree of refinement required will vary across topics. Some topics begin with clear and relevant Key Questions and well-defined PICOTS that accurately reflect the clinical logic; in these cases little may change during the topic refinement stage. Other topics may be less clear or complete and require more substantial refinement. In either case, all topics undergo the entire topic refinement process.

### The Topic Refinement Team

Topic refinement requires a variety of skills. Members of the team should have (1) expertise in the methods of systematic review research, (2) knowledge of health care and/or health services, (3) the ability to search and understand health care research literature, (4) the ability to converse fluently with topical experts, (5) the ability to effectively engage stakeholders, (6) skill in the methods described in this report, and (7) project management skills. In addition, a topic refinement team needs to have knowledge of the particular health care topic of interest. It is not expected that each or any member of the team will have all of these skills, just that they have the skills collectively as a team.

EPCs have configured their topic refinement teams in different ways. Teams may include one or more investigators (M.D. or Ph.D.), one or more research associates/assistants, and a research librarian. Depending on the topic, this core team might be supplemented with a topical expert and/or a statistician. Some EPCs use a dedicated core team that leads all of the EPC's topic refinements. Other EPCs employ a single team to lead both topic refinement and the systematic review. Each approach has its own advantages and disadvantages, and EPCs should consider which approach best suits their organization and resources.

The use of a dedicated topic refinement team has the advantages of consistency, efficiency, and iteratively improved expertise. An experienced team that has conducted multiple topic refinements may acquire finer skills in the topic refinement process. In addition, having a dedicated topic refinement team may help to clearly distinguish the different objectives of the refinement stage and the systematic review stage. The goal of topic refinement is to formulate the questions, and the goal of the systematic review is to answer those questions. When formulating the questions it is important not to let considerations of the possible answers overly influence the formulation of the questions. This may be more difficult to achieve if the refinement and systematic review teams are the same.

An advantage to using a single team is improved continuity and efficiency throughout the topic refinement and systematic review process. When the systematic review commences, the team will already be familiar with the topic, facilitating the transition from the topic refinement phase to the systematic review phase. In addition, if further evolution of the Key Questions, analytic framework, and PICOTS is needed the team will be familiar with the issues considered during refinement, which may facilitate decisions about any additional changes to the topic. EPCs using a dedicated topic refinement team approach have addressed this need for continuity between the stages by including at least one of the topic's systematic review investigators as a member of the refinement team.

### Initial Topic Refinement Phase

During the initial topic refinement phase, the topic refinement team will conduct an additional literature scan to supplement the guidance compiled during topic nomination and development. The purpose of this literature scan is two-fold: (1) to help the investigators better understand the topic, its clinical logic, and the decisional dilemmas; and (2) to familiarize the team with the extent of the relevant literature. The literature scan is a targeted search and review of the evidence, which is not fully synthesized. The intent of the literature scan is to provide insight about the research feasibility, relevance, and scope of the subsequent systematic review.

The members of the topic refinement team will not necessarily be experts in the topic, in which case they may conduct informational interviews with topical experts. These interviews provide insight into technical issues, controversies, and the current state of knowledge about the topic. Specific interview questions should be crafted to help clarify basic issues of the topic or uncertainties that arise in the course of reviewing the topic nomination materials and the literature scan.

Guided by a literature scan, input from topical experts, and discussions among themselves, the team develops the provisional PICOTS, analytic framework, and Key Questions. These provisional forms of the essential topic elements will then be used as the basis for interviews with the Key Informant panel (described below). The PICOTS, analytic framework, and Key Questions are interdependent and complementary, and usually evolve together—with changes in one usually carrying through to the others.

Appendix B provides an example from an actual review to illustrate the refinement of a few aspects of a topic. Figure B1 shows the changes to the preliminary nominated PICO (without Timing or Setting) and the nominated question of interest as they were refined into their provisional form. Table B1 charts the identified need for changes to particular elements of the nominated topic, the changes that were made, and the rationale for the refinements. This appendix does not provide a comprehensive description of the entire refinement of the topic. Rather, it illustrates a systematic approach to refining a select few aspects of a single topic. Such an approach can be comprehensively applied to the initial refinement of all aspects of a given topic.

#### PICOTS

The provisional PICOTS should be patient-centered and relevant for decisionmaking, regardless of what the topic refinement team anticipates will be found in the current literature.5 For example, outcomes that matter most to patients, such as quality of life or morbidity, are generally more important than intermediate outcomes such as biomarker values. And, comparators that reflect real-world clinical practice or standard of care (and hence are relevant to decisionmaking) are generally preferable to placebo or no treatment.

Refining the PICOTS often involves a balance and tradeoffs between the different PICOTS elements; i.e., inclusion of one element might have restrictive implications for other elements. For example, an outcome of particular interest may not be applicable to certain subpopulations; or constraining the population of interest may limit the relevance to certain interventions. When making refinement decisions about the PICOTS, the topic refinement team considers the principles discussed above, including fidelity to the nomination, scope, relevance, and research feasibility.

#### The Analytic Framework

The analytic framework illustrates the relationships between the PICOTS and the Key Questions; these inform the systematic review scope and inclusion criteria. This can be useful for both the investigators and the end users of the systematic review—especially when the questions represent a complex logic chain—because the framework highlights the decisional context of Key Questions. The analytic framework depicts our understanding and assumptions of the clinical, biological, or health services underpinnings of the mechanisms through which an intervention is presumed to affect outcomes. Patient-centered outcomes occupy the final causal position in the framework. Causal intermediates or surrogates of the primary outcomes are shown more proximally in the framework. These “intermediate outcomes” are important if associated with patient-centered health outcomes or important for decisionmaking.

The choice of patient-centered and intermediate outcomes reflects the priorities and values of stakeholders and the clinical logic of the topic. An understanding of the clinical logic may come from the literature scan, input by topical experts, and/or the topic refinement investigator's expertise. This may be affirmed or revised later by input from Key Informants or public commentary. The analytic framework has been described in more detail previously.7-10 An example of an analytic framework is in Appendix B.

#### Key Questions

The Key Questions guide the systematic review. As with the analytic framework, the Key Questions reflect the clinical logic and the important decisional dilemmas of the topic. A fundamental goal of topic refinement is to formulate precise, detailed, and clearly focused Key Questions that elucidate the health care issue of interest. At a minimum, the questions explicitly include the basic elements of population(s), intervention(s), comparator(s), and outcome(s) (PICO). They may also include timing and setting (TS). Each element of the PICOTS and their respective relationships should be specifically and unambiguously described.

Good Key Questions are formulated without judgments about the likelihood of the extant literature to answer them. The Key Questions address patient-centered health outcomes (e.g., quality of life, mortality, hospitalization rates), intermediate outcomes (e.g., diagnostic test characteristics, biomarker values), harms, and factors that may influence effect estimates and introduce heterogeneity in results. To investigate these factors, investigators may include additional Key Questions about subpopulations, different forms of the intervention, or specific settings. See Appendix B for an example of provisional Key Questions.

#### Engaging Stakeholders as Key Informants

The topic refinement team obtains input from stakeholder groups through the engagement of Key Informants. The Key Informant panel is a small number of individuals, who reflect the perspectives of those who would make decisions with the findings of the report, as well as those who would be affected by those decisions. Key Informant input can improve the systematic review, help ensure that the research reflects the needs of diverse groups, and facilitate the diffusion and implementation of findings.

Key Informants provide:

- Opinions about the preliminary Key Questions, PICOTS and analytic framework.
- Input about issues not adequately addressed in the initial topic refinement phase.
- A spectrum of relevant views about technical aspects of the topic, stakeholder priorities, standards of care and potential dilemmas or controversial decision points.
- Input about the most important outcomes for decisionmaking.

Key Informants also provide input from diverse viewpoints. For example these individuals may: describe their experiences with a particular technology; share their opinions about the advantages or disadvantages about specific treatments; describe usual care from the perspective of their organization or specialty; share their opinions about the contribution of the proposed systematic review in improving health care; and/or elucidate important factors and values that affect their decisionmaking (see Appendix A for additional detail). With this input the topic refinement team can better understand real-world context; decisional dilemmas from a variety of perspectives; and controversies and reasons for divergent views. This in turn helps to inform the scope of the review, and improves the relevance and applicability of the results of the evidence review for decisionmakers.

##### Identifying and Recruiting Key Informants

The topic refinement team first identifies relevant stakeholder categories for the Key Informant panel. The team should ensure that the Key Informants represent the diversity of viewpoints on the topic. Unless clearly not relevant for a particular topic, patients or their representatives should always be included. The importance of other stakeholder groups will vary according to the topic and the particular issues or dilemmas to be considered. For topics known to be controversial or associated with particularly challenging dilemmas, Key Informants representing the important opposing viewpoints should be enlisted. Although the number of Key Informants varies by topic and the nature of the questions of interest, the typical range has been 6 to 12 individuals.

The topic refinement team may have a preliminary list of stakeholders from the topic nomination development phase. Key Informants might be identified by contacting professional, industry, or advocacy organizations; by contacting experts whose publications are identified in the literature scan; by referral of the AHRQ Project Officer, who may know of relevant stakeholders who have participated in the EHC Program; by referral of topical experts; or by referral of potential Key Informants (both those who elect to participate and those who do not).

Recruitment and scheduling of Key Informant interviews can be time consuming. Generally it requires multiple communications and coordination of schedules. Some potential Key Informants will decline to participate or will be unavailable during the designated timeframe. Therefore, making a prioritized list of more than one potential candidate for each stakeholder category is helpful. The initial invitation to participate should include a brief introduction to the EHC Program and their role in the topic refinement process; a description of the topic and the interview process; and information about the time and preparation required to participate.

##### Composition of Key Informant Interview Groups

The topic refinement team considers various factors when grouping Key Informants for interviews. These factors include the number of individuals, the types and variety of stakeholder groups, and the specific issues to be addressed. Determining the desired composition of the groups for individual interviews requires the judgment of the topic refinement investigators. For example, if the interview were to focus primarily on an issue requiring particular expertise, the size and heterogeneity of the group could be limited. Similarly, if the topic refinement investigators sought to explore the tension between differing views of an issue, a larger and more heterogeneous group might be desirable (e.g., a patient advocate, a clinician, and an industry representative). Patients or consumers may be more comfortable expressing their views when in a single stakeholder group. The team should carefully consider the type of information needed to further refine the topic and then compose the individual Key Informant interview groups accordingly.

The size of the group in a single interview may affect the quality of engagement, the detail and depth of the discussion, and the ease of facilitating the interview. An overly large group may not allow for all Key Informants to fully express their views within the allotted time. Similarly, trying to hear from too many participants and to address all questions on the interview agenda may preclude exploration of a particular question to the desired level of detail. Compared with smaller groups, a large group is more likely to include participants with a wider diversity of opinions, personalities, and communication styles, all of which may challenge the interviewer's ability to guide and focus the discussion. Larger groups might be viable if the issues for discussion are limited and the Key Informant group is sufficiently homogeneous. Larger groups do offer the potential advantage of reducing the time demand on the topic refinement team; but this advantage may not outweigh the disadvantages.

Determining the best size and composition of interview groups involves balancing the factors mentioned above with practical considerations such as the interview timeframe, schedules of the Key Informants, and available time of the topic refinement team. In our experience, two to four Key Informants per interview is effective and efficient for most topics. For eliciting very specialized and/or voluminous information, one-on-one interviews with particular individuals may be beneficial.

##### Conducting Key Informant Interviews

Key Informant interviews provide a means for the topic refinement team to gather information and better understand stakeholder opinions, values, and priorities. Consensus among participants however is not the goal. Generally, the team conducts interviews over a period of about 3 to 4 weeks, followed by several additional weeks to synthesize and incorporate input. The interviews are not conducted with the same high level of methodological and analytical rigor that would be used in focus group research (e.g., coding of transcripts, reaching saturation). Rather, they are an efficient way of eliciting input from stakeholders in as complete and thorough a manner as possible within the practical timeframe of the overall systematic review process.

The interviews are usually conducted via teleconferencing, although face-to-face interviews are sometimes possible. The interviews are scheduled to allow adequate time (typically about 60 to 90 minutes). Oftentimes a core member of the topic refinement team facilitates the interviews. Adequate preparation is essential to successful Key Informant interviews. Key Informants are sent advance materials that review the general purpose of topic refinement and clarify their role in the process; the provisional PICOTS, Key Questions, and analytic framework; and a list of the salient issues and questions to structure and guide the discussion. The list should also include open-ended, jargon-free questions that invite input on any aspect of the topic.

In preparation, the topic refinement team generates a well-considered list of clear and specific discussion questions to guide and structure the interviews. These should be questions about which the team is uncertain and/or which require the input of particular stakeholders. These may be questions that the team has not been able to adequately address with the literature search or in discussion with topical experts, or they may be questions that require additional stakeholders' perspectives, experience, or viewpoints. Questions that explicitly invite comments on the provisional PICOTS, analytic framework and Key Questions can provide useful input that might not emerge spontaneously. In particular, a question about which outcomes are important for stakeholders in making decisions can improve the relevance of the systematic review. And, asking for general input not specific to prepared questions may elicit important unanticipated perspectives.

The facilitator may open the interview by briefly reviewing the essential information contained in the preparatory materials. Such an introductory review will help clarify the goals of the interview, the meaning of PICOTS, the analytic framework, etc. Effective facilitation is essential for effective Key Informant interviews, and the general principles of effective facilitation have been described elsewhere.12 Critical elements of good facilitation include assuring that all participants are included and allowed to fully express their views; posing effective followup questions that clarify and/or probe the subject more deeply; synthesizing various contributions and advancing the discussion by reformulating questions or just moving to the next agenda item; and reserving one's own opinion beyond that required to elicit and explore the views of the participants. Ultimately, effective facilitation requires good familiarity with the topic and the issues faced in the initial refinement.

The facilitator's job can be more challenging if the group is heterogeneous, either by design or circumstance. Generally, for a more diverse mix of Key Informants, the facilitator should emphasize questions at the intersection of the participants' varied backgrounds. For example, in an interview that includes a patient advocate and a clinician, the facilitator should avoid medical jargon and technical issues and emphasize questions for which all group members can be expected to have an opinion on an equal basis.

A detailed record of the interviews can be useful for reliably considering all relevant input. Such a record also aids the team in producing a summary report that accurately depicts the interviews and the decisions reached by the team. Various methods are used across EPCs to document the content of Key Informant discussions. Typically minutes are taken of interviews and circulated to participants. Recording and transcribing the interviews provides an even more complete record. Team members from at least one EPC use a standard form for this purpose. The form includes sections for (1) recording participants' input related to specific PICOTS elements, (2) observations and thoughts of the team member, and (3) questions as to whether any issues raised should be incorporated into future interviews and/or warrant specific refinements to the topic. It provides a structure for debriefing after the interview and helps ensure that important issues are not missed in the synthesis once all the interviews have been completed.

#### Integration and Synthesis

An essential aspect of the topic refinement process is the integration and synthesis of the information that the team gathers from various sources (literature scan, topical experts, and Key Informants). They consider whether to integrate this input, and how it will affect the analytic framework, Key Questions and PICOTS. These decisions about integration and synthesis are informed by the guiding principles. The importance of each principle may vary by topic, and the team will consider the extent to which a principle is applied, and the balance of one principle with another. Although this report describes effective practices and approaches to topic refinement, the variability between topics makes it impractical to apply the principles in a prescriptive manner. Some issues of synthesis were mentioned in the guiding principles section; this section discusses in greater detail how topic refinement investigators may balance specific principles.

Some refinement decisions are straightforward, and the team may incorporate information that addresses those issues in the course of gathering the information. For example, a nomination might not specify all subclasses of an intervention drug of interest, and the team might easily clarify with the literature scan or topical expert that an additional subclass is also clearly relevant. For other issues the team may intentionally delay a decision to gather additional input because the issue is complex, controversial, or best addressed by another source of information. For example, a Key Informant might indicate that a proposed outcome measure is not appropriate even though the literature scan showed that the measure is commonly used. In such a case, the team might wait to discuss the issue with subsequent Key Informants and/or topical experts before making a decision. Occasionally an issue previously settled is reconsidered in light of additional information or a subsequent decision about another issue.

The team may encounter various challenges in deciding how to synthesize different information, particularly when sources of input conflict. Differences may arise between the original nomination and Key Informant input. For example, the topic nominator may intend to use the systematic review as the foundation of a clinical guideline, and will specify particular interventions. Key Informants may identify additional interventions and comparators that reflect clinical practice and decisional dilemmas. The team will then balance fidelity to the original nomination with responsiveness to stakeholder input and suitable scope to ensure that the systematic review is relevant and useful to the nominator and for other stakeholders.

In other instances Key Informants may disagree on an issue. The team cannot be responsive to all input, and must judiciously decide which input to integrate. In making these decisions, the topic refinement investigator can consider the nature of the evidence, the opinions of experts, the team's own expertise with the topic and/or systematic review methods, and other EHC program principles such as patient-centeredness and public health relevance.

If a topic is limited in its scope by the needs of the nominator or input from Key Informants, the literature scan might reveal a small evidence base, in which case the team may have to balance the research feasibility of the topic with programmatic considerations about the broader relevance and usefulness of the proposed review. In other cases, the literature scan may reveal a large evidence base after further refinement of the clinical logic with Key Informant input; and the team may have to balance responsiveness to stakeholder input, research feasibility, and suitable scope to yield a useful and timely review.

#### Reporting

The multiple opportunities for modifying a topic underscore the importance of consistently reporting decisions and the team's rationale for those decisions. This is important for the topic refinement team, for AHRQ, and for other EPC colleagues who may undertake the topic when it proceeds to the evidence review phase.

The topic refinement summary report documents the evolution of a topic through the refinement process, and may be used as a reference throughout the lifecycle of the topic in the EHC program. The topic refinement team may use this document for internal communication about reasons for changes through the topic refinement process. For the evidence review team, the topic refinement summary report may provide an historical document to understand previous decisions, inform discussion of similar issues, accurately respond to the Technical Expert Panel or peer reviewers about decisions made during topic refinement, assist with framing controversial issues in the evidence report, and contribute to discussion of future research needs in the evidence report. The AHRQ program officer may refer to this document to respond to stakeholder queries and to ensure consistency with EHC principles and criteria.

Generally the topic refinement summary report:

- Documents the evolution of a topic and explains refinement decisions, particularly when there is a clear alternative.
- Summarizes input from topical experts, Key Informants, the literature scan, and public reporting.
- Documents responses to input
- Points to areas of conflicting input.
- Highlights areas that remain unresolved.

Historically, the topic refinement summary reports have not included formal documentation of changes made after public posting of the draft Key Questions, PICOTS and analytic framework; or details of the initial literature scan. These changes are reported in other documents generated during the topic refinement process.

The workgroup observed variability in the content and level of detail in individual summary reports in the following areas:

- Documentation of topical expert discussions.
- Key Informant input, though much greater detail was found in the Key Informant call minutes.
- Documentation of changes to Key Questions and PICOTS.
- The rationale for changes to Key Questions and PICOTS, especially those made prior to Key Informant input.
- Description of decisional issues or controversies, and how different priorities or inputs were considered by the topic refinement team.
- Documentation of considerations given to the literature search.

The workgroup noted that other documents generated in the course of topic refinement (e.g., call minutes with the Project Officer and Key Informants) sometimes provided highly detailed documentation of discussions. However, the topic refinement summary reports frequently did not capture sufficient detail about the important issues and decisions that affected the topic scope.

While transparency does not require detailed documentation of every change and step in the process, disclosure is important for establishing confidence in the refined document—the confidence of patients, reviewers, nominators, decisionmakers, and policymakers. To improve the transparency and consistency of reporting, the workgroup recommended and integrated guidance into the updated topic refinement document (Appendix A):

- Detailed description of important and/or potentially controversial issues that arose during the topic refinement process.
- Summary of relevant points of the topic refinement team's discussion of controversial issues or issues that required balancing different viewpoints.
- Greater detail of rationales for revisions to the topic, including what changed, the timing, and information considered (i.e., literature scan, Key Informant input, topic refinement guiding principles).
- Inclusion of possible refinements that were considered, but did not result in a change.
- Inclusion of possible refinements that require additional future input (public commentary, Technical Expert Panel input, a more focused literature scan, etc.) or are otherwise more appropriate for the evidence review phase.
- Documentation of these changes in an easy-to-read tabular format.

Although the full topic refinement summary report is not posted publicly, the analytic framework, PICOTS, and Key Questions are posted for public comment (see next section). In addition, a high-level summary of input and changes are reported in the protocol during the systematic review stage.

#### Public Posting

In addition to Key Informant interviews, public posting offers an important means of capturing input from a broader sample of stakeholders. This also promotes transparency and stakeholder input, important aspects of the EHC Program. A document outlining the proposed scope (draft Key Questions, PICOTS, and analytic framework) is posted for public comment on the EHC Web site for 4 weeks (see Appendix A). The document also provides sufficient background to apprise the reader of the importance of the topic, uncertainties pertaining to clinical practice, potential impact on patient care, and the potential contribution of the proposed review. Any individual may comment; and commenters have included patients and other consumers, advocacy organizations, health care professionals, professional organizations, and industry representatives. Public comments may provide additional insights about the relative importance of outcomes and PICOTS elements to specific stakeholders, relevance of questions, additional relevant and interested stakeholders, clarity of wording, and potential approaches to frame the eventual evidence report.

Some individuals may attempt to answer the Key Questions rather than to comment on them. Nonetheless, such responses are still of value because they may point to relevant literature and guidelines, identify ongoing work by other organizations, highlight areas of low and high clinical uncertainty, provide insight into clinical or usual practice, and affirm the need for a new review. For example, for a recent review on inguinal hernia repair,22 public input affirmed the importance and relevance of the topic and provided comments about certain procedures most commonly performed in the United States. This input affirmed that the review addressed the diversity of decisions and factors in inguinal repair, including surgical approach, fixation technique, mesh type, surgical experience, and setting. It also resulted in the elimination of two questions related to nonmesh procedures; expansion of questions related to three distinct populations; and reorganization of questions pertaining to mesh types and fixation methods.

At the end of the public comment period, the topic refinement and/or systematic review team reviews all comments. Additional revisions are documented in the topic refinement summary report. The revised Key Questions, PICOTS, analytic framework, and general highlights of comments and responses are included in the systematic review protocol. These elements are considered final after input from the Technical Expert Panel during the conduct of the systematic review.