# References

1 (2009). Federal Coordinating Council for Comparative Effectiveness Research. Report to the President and the Congress.
2 U.S. Preventive Services Task Force. (2012).
3 Agency for Healthcare Research and Quality. (2002). Medicare Uses of AHRQ Research Fact Sheet.
4 DERP. Drug Effectiveness Review Project. (2012).
5 Whitlock E, Lopez SA, Chang S, et al. (2010). AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective HealthCare program. J Clin Epidemiol.
6 Counsell CC. (1997). Formulating questions and locating primary studies for inclusion in systematic reviews. Ann Intern Med.
7 Battista RN, Fletcher SW. (1988). Making recommendations on preventive practices: methodological issues. Am J Prev Med.
8 Harris RP, Helfand M, Woolf SH, et al. (2001). Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med.
9 Helfand M, Balshem H. (2010). AHRQ Series Paper 2: Principles for developing guidance: AHRQ and the Effective Health-Care Program. J Clin Epidemiol.
10 AHRQ. (2010). Methods Guide for Medical Test Reviews: Agency for Healthcare Research and Quality.
11 Helfand M, Balshem H. Principles in Developing and Applying Guidance. Methods Reference Guide for Comparative Effectiveness Reviews.
12 Effective Health Care Program. (2012). The Facilitation Primer: Strategies, Tools & Considerations to Get You Started.
13 Hickam D, Weiss J, Guise JM, et al. (2013). Outpatient Case Management for Adults with Medical Illness and Complex Care Needs.
14 Saha S, Smith B, Totten A, et al. (2013). Pressure Ulcer Treatment Strategies: A Comparative Effectiveness Review.
15 Lin J, Webber E, Beil T, et al. (2012). Fecal DNA Testing in Screening for Colorectal Cancer in Average-Risk Adults.
16 Chou R, Cottrell E, Wasson N, et al. (2012). Screening for Hepatitis C Virus Infection in Adults.
17 Chou RC, Hartung D, Rahman B, et al. (2012). Treatment for Hepatitis C Virus Infection in Adults.
18 Agency for Healthcare Research and Quality. Identifying and Managing Nonfinancial Conflicts of Interest for Systematic Reviews, Methods Research Report.
19 Kemper A, Coeytaux R, Sanders G, et al. (2011). Disease-Modifying Antirheumatic Drugs (DMARDs) in Children With Juvenile Idiopathic Arthritis (JIA).
20 Effective Health Care Program. (2009). Point-of-Care Testing for HbA1c—Nomination Summary Document Agency for Healthcare Research and Quality.
21 Effective Health Care Program. (2008). Enzyme Replacement Therapy for Lysosomal Storage Disease—Nomination Summary Document Agency for Healthcare Research and Quality.
22 Treadwell J, Tipton K, Oyesanmi O, et al. (2012). Surgical Options for Inguinal Hernia: Comparative Effectiveness Review.