# Methods

We convened a work group consisting of four investigators from four different EPCs in the United States and Canada and one Project Officer from AHRQ. All investigators had direct experience conducting topic refinements for the EPC Program and the Project Officer had broad experience of the topic refinement process as it has been followed across numerous EPCs. In addition, a research associate with experience as a topic refinement team project manager provided input on the logistics and management aspects of the topic refinement process.

Our work group followed previously described basic principles for developing methods guidance in the EPC program.9 In particular, we recognized that the subjectivity and variability inherent in the topic refinement process limits the use of empirical evidence in developing guidance. Therefore, our work group used a best-practice approach based upon (1) the direct topic refinement experience of the work group members, (2) our critical assessment of completed topic refinements from other EPCs, and (3) input on an initial draft of this report from EPC investigators representing all but one AHRQ EPC.

As a first step, work group members each described their own EPC's approach to topic refinement, including their routine procedures as well as perceived strengths, challenges, and problems with the approach. The AHRQ Project Officer then described successful and unsuccessful procedures used by other EPCs not directly represented by the work group members. In this way, group members gained familiarity with the procedures of other EPCs, identifying shared practices as well as unique aspects of each EPC's topic refinement process. Next, each work group member individually reviewed three topic refinement summary reports and other pertinent documents (such as call minutes, disposition tables, and protocols) previously produced by EPCs other than their own. We compared these to elucidate: (1) similarities and differences between the elements of the original PICOTS and the Key Questions that were refined, (2) rationales used in making refinements, (3) sources of input that influenced the decisions to refine (e.g., topic refinement team judgment, Key Informant input, literature scan), and (4) how the process was reported.

Based on these careful examinations of current practice in topic refinement, we compiled a list of questions for the work group to consider in detail. These questions addressed a range of issues and concepts that were (1) challenging for many EPCs, (2) incompletely articulated in topic refinement summary reports, and/or (3) especially variable between EPCs. We generated an initial list of 33 items, which we consolidated according to common themes into a list of 17 items for the work group to discuss. In the course of our deliberations, we further consolidated these items and categorized the relevant issues into three main categories, as presented in the Results section of this report: The overall purpose of topic refinement; guiding principles; and the mechanics of conducting a topic refinement.

We discussed each of the items during eighteen 90-minute teleconference meetings over 12 months. All meetings were audio recorded, and detailed minutes of the meetings were subsequently reviewed and discussed by all group members. When possible, the work group strove to elaborate on the basic description of topic refinement contained in the Topic Refinement Document, particularly regarding various elements of the mechanics of conducting a topic refinement such as the initial topic refinement, engaging stakeholders, synthesis, and reporting. We also strove to assess critically each item on the list and to synthesize a set of recommendations to guide the topic refinement process. We worked to achieve consensus in our recommendations regarding general guiding principles. Recognizing the legitimate variability in the requirements of different topics and in approaches to the mechanics of topic refinement, we sought to describe different viable approaches and discuss their relative merits. EPC investigators representing all but one EPC provided input on the draft report. Additional experts in systematic review were invited to provide external peer review of this draft report; AHRQ and an associated editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments and revised the final report as appropriate.