# Introduction

“A prudent question is one-half of wisdom.”

— Francis Bacon

Systematic reviews aim to improve health outcomes by developing evidence-based information about which interventions are most effective for which patients under specific circumstances, and to disseminate that information to patients, clinicians, and decisionmakers.1 Systematic reviews are used by a variety of organizations to inform clinical guidelines,2 health care policies,3 and insurance coverage decisions.4 The Evidence-based Practice Center (EPC) Program, part of the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care (EHC) Program, conducts systematic reviews on topics related to a range of health care issues nominated by a variety of stakeholders. Stakeholders may represent patients, consumers, advocacy organizations, clinicians, researchers, agencies that issue guidelines, policymakers, industry, or health care organizations. Involving stakeholders in the nomination process provides an opportunity for end users of research to participate in asking and answering questions about health care.

To provide useful answers, systematic reviews must ask the right questions. Challenges arise when stakeholder-nominated topics are not ideally formulated for the broadest public health and/or clinical relevance, or not formulated to be researched feasibly using accepted systematic review methods. Additionally, nominations might not ideally reflect the state of the science or technical aspects of the topic. Conducting systematic reviews may be difficult or impossible for topics that are inadequately precise or overly inclusive in their description of the populations, interventions, comparators, and/or outcomes of interest. Alternatively, topics that are overly narrow might be feasibly expanded to have broader relevance than that intended in the original nomination. To ensure that systematic reviews provide the most useful answers, topics nominated by stakeholders generally need to be refined so that the Key Questions are relevant and feasibly researchable.

In 2007, investigators with the EPC Program began developing methods for topic refinement that were iteratively modified and eventually formalized into a Topic Refinement Document (Appendix A). Since 2009, the program has used this document as a guide for systematically conducting topic refinements and as a template for drafting summary reports for individual topic refinements. To date, this document has provided the most complete methodological guidance for topic refinement. Although the Topic Refinement Document stipulates the required phases and common elements of topic refinement, different EPCs have approached specific aspects of topic refinement in both similar and different ways. This variation among EPCs provided an excellent opportunity to learn and consider the advantages and disadvantages of different approaches to topic refinement. Therefore, AHRQ convened a work group to synthesize and assess current approaches to topic refinement and to develop methods recommendations for best practices. This report details the work group's findings, including guiding principles and methodological recommendations that may help investigators to effectively refine topics for systematic reviews, both within and outside of the EPC Program.