# Peer Reviewers

Michelle Brasure, Ph.D.

Project Director, Minnesota

Evidence-Based Practice Center

Minneapolis, MN

Timothy S. Carey, M.D., M.P.H.

Co-Director, RTI-UNC

Evidence-Based Practice Center

University of North Carolina at Chapel Hill

Chapel Hill, NC

Emma Irvin, B.A.

Director, Research Operations, Systematic Review Program

Institute on Work & Health

Toronto, ON, Canada

Joseph Lau, M.D.

Program Director, Tufts University

Evidence-Based Practice Center

Tufts Medical Center

Boston, MA

Melissa McPheeters, Ph.D., M.P.H.

Co-Director, Vanderbilt

Evidence-based Practice Center

Vanderbilt University Medical Center

Nashville, TN

Denise O'Connor, Ph.D.

Editor, Cochrane Effective Practice and Organization of Care Group

Australasian Cochrane Centre

Monash University

Victoria, Australia

Parminder Raina, Ph.D.

Director, McMaster University

Evidence-Based Practice Center

McMaster University

Hamilton, ON, Canada

Thomas Ratko, Ph.D.

Associate Director, Blue Cross Blue Shield

Evidence-Based Practice Center

Technology Evaluation Center

Washington D.C.

Gillian Sanders-Schmidler, Ph.D.

Director, Duke University

Evidence-Based Practice Center

Duke University

Durham, NC

Jodi Segal, M.D., M.P.H.

Associate Director, Johns Hopkins

Evidence-Based Practice Center

Johns Hopkins University School of Medicine

Baltimore, MD

Paul Shekelle, M.D., Ph.D.

Director, Southern California

Evidence-Based Practice Center

RAND Corporation

Santa Monica, CA

Jonathan R. Treadwell, Ph.D.

Associate Director, ECRI Institute

Evidence-Based Practice Center

ECRI Institute

Plymouth Meeting, PA

C. Michael White, Pharm.D., FCP, FCCP

Director, University of Connecticut

Evidence-Based Practice Center

University of Connecticut

Hartford, CT