# Acknowledgments

The authors gratefully acknowledge and thank the following individuals for their contributions to this project: Basmah Rahman, M.P.H., and Ngoc Wasson, M.P.H., for their administrative and project management support; Leah Williams, B.S., and Jeannine Ouellette for editing and formatting this paper; and associate editors Stephanie Chang, M.D., M.P.H., and Mark Helfand, M.D., M.P.H., M.S.