# Conclusion

To date, EPCs have conducted approximately 100 topic refinements. These topics represent a broad and diverse range of health care issues, each with its own clinical dilemmas, technical questions, coverage implications and/or policy challenges. Although the EHC Program stipulates the phases and common elements of topic refinement that EPCs must include, various EPCs have approached aspects of topic refinement in both similar and different ways. This variation among EPCs provided an excellent opportunity to learn and consider the advantages and disadvantages of different approaches to topic refinement. Our work group has reviewed the approaches used by various EPCs. We critically assessed the topic refinement process, and identified lessons learned. We have developed a set of guiding principles and identified practical approaches to conducting a topic refinement. The points of our report are presented in Box 3. Through the review of topic refinement summary reports, we offer recommendations to improve the reporting and transparency of the topic refinement process. Given the variability between topics and topic refinement investigators, these recommendations are not meant to be prescriptive. Skilled investigators must inevitably apply judgment and discretion in refining topics. Therefore, we envision investigators using these principles for more systematic and explicit decisionmaking.

Box 3 Key points

♦ The goal of topic refinement is to produce a topic that addresses important health care questions and dilemmas; considers the priorities and values of relevant stakeholders; reflects the state of the science; and allows for application of systematic review research methods.
♦ The guiding principles are: fidelity to the original nomination, relevance, research feasibility, responsiveness to stakeholder input, reduction of potential investigator bias, transparency, suitable scope.
  ○ These principles are consistent with EPC program topic selection criteria for systematic reviews and the principles for conducting systematic reviews.
♦ Variability of topics in the EPC program makes it impractical to apply the guiding principles in a prescriptive manner.
♦ Topic refinement is an iterative and phased process. The stages of topic refinement (Figure 2) are:
  ○ Initial topic refinement
  ○ Key Informant interviews
  ○ Public comment period
  ○ Synthesis and reporting
♦ Initial topic refinement gathers information from topical experts and a literature scan to develop the provisional PICOTS, analytic framework (AF), and Key Questions (KQs) of the topic to present to key informants for input.
♦ The Key Informant panel is comprised of 6 to 12 individuals. They reflect the perspectives of stakeholder groups who would make decisions with the findings of the report, as well as those affected by those decisions. Their input can improve the relevance and applicability of the systematic review.
  ○ To facilitate the recruitment process, a good practice is to make a prioritized list of more than one potential Key Informant for each category.
  ○ Commonly, 2-4 individuals are engaged at a time for interviews to allow for sufficient opportunity to express opinions and for interaction. Consensus is not a goal.
  ○ The team ensures that the group's mix of expertise and viewpoints are complementary.
  ○ Interviews are usually 60-90 minutes in duration, and conducted over 3 to 4 weeks.
  ○ The interviews are generally facilitated by a core member of the topic refinement team, with part or all of the topic refinement team in attendance.
♦ Public comment on the topic allows for input from a broader range of individuals.
♦ Synthesis of input requires judgment of the topic refinement team and consideration of the guiding principles. The investigators may balance certain principles when making decisions about whether and how to include comments from individual stakeholders or other sources of input, especially when they are conflicting. The topic refinement team is comprised of independent investigators; ultimately they are responsible for decisions about integration of input.
♦ In reporting, all decisions should be concisely and transparently documented in the topic refinement summary report. This report may be used by the topic refinement team, systematic review team, and AHRQ program officer to understand decisions made during topic refinement. It includes:
  ○ a summary of input (topical experts, literature scan, Key Informant, and public commentary)
  ○ important and/or critical issues that were raised
  ○ description of controversial or unresolved issues
  ○ changes in the PICOTS, KQs or AF, and the rationale in light of the guiding principles

While these recommendations can enhance and improve the process of topic refinement, our approach was limited in a number of ways. We were not able to assess the effect of topic refinement on the content of the systematic review, nor could we assess its effect on the uptake and presumed usefulness of the systematic review by stakeholders. While the opportunity existed to review public and peer review comments of the draft systematic reviews, the ability to make conclusions about the effect of topic refinement (or its elements) would be limited because of the input of other stakeholders during the systematic review process; other elements that affect perceived usefulness; and readability. While the topic refinement process is described as a linear process, oftentimes it is iterative and topic refinement summary reports may not reflect all considerations of investigators. The workgroup had a limited number of individuals from the EPC program, and thus a limited number of perspectives, but all workgroup members had experience in topic refinement across various EPCs, and the Project Officer had substantial additional experience working with other EPCs. Additional insights from direct contact with other EPC investigators might have informed our results. However, we did receive critical input from EPC investigators representing all but one AHRQ EPC, and we revised the final report accordingly.

The EPC Program's current methods for topic refinement were developed and have iteratively evolved since 2007. In that time, investigators learned lessons about the relative strengths and limitations of various approaches and aspects of topic refinement. The recommendations in this report were developed from our work group's synthesis and assessment of approaches used by various EPCs to date. Questions still remain about many facets of the topic refinement process. How to most effectively identify and engage stakeholders? How to better understand the effects of the inherent subjectivity of the process and to modulate those effects when possible? We expect that methods will continue to evolve and that more will be learned about the best approaches to these and other challenges.