# Appendix B Example of Selected Aspects of a Topic Refinement

Appendix Figure B1 Nomination: The effectiveness of disease-modifying anti-rheumatic drugs in children with juvenile idiopathic arthritis

Note: DMARD= disease-modifying anti-rheumatic drug, JIA=juvenile idiopathic arthritis, KQ=key question, NSAID=nonsteroidal anti-inflammatory drug, PICO=population, intervention, comparator, outcome.

This set of figures use the example of a review entitled “The effectiveness of disease-modifying anti-rheumatic drugs (DMARDS) in children with juvenile idiopathic arthritis (JIA)” to illustrate how treatment of JIA in children with DMARDs versus intra-articular corticosteroids and NSAIDs may result in intermediate outcomes (e.g., changes in laboratory measures of inflammation, changes in the active joint count, or radiologically evident progression of disease) and/or long-term outcomes (e.g., clinical remission, changes in quality of life, changes in growth, and changes in development). In addition, adverse events may occur at any point after the treatment is received. The examples of select aspects of topic refinement are shown in 3 sections: Nomination, changes to elements of the nominated topic, and the example analytic framework illustrating the integration of the key questions into the topic. The Nomination section figure depicts the key questions within the context of the PICOTS described the methods section.

Appendix Table B1 Changes to elements of the nominated topic with rationale for refinements

Original Element | Source of Input | Comment | Decision | Change | Rationale
Nominated KQ | Local expert, literature scan | There are at least six subtypes of JIA, with distinct clinical characteristics and different treatment approaches. The amount of published literature for each subtype varies substantially. | Specify in the KQ that subtypes of JIA exist and that the population of interest will include children with any subtype. | - No change in PICO.; - KQ 3 was added about possible variations in effectiveness and safety of DMARDs between subtypes. | Added detail about subtypes makes the key questions more specific, and improves the accuracy and research feasibility of the SR. Inclusion and analysis by JIA subtypes might expand the scope and heterogeneity of the SR; however the literature predominately addresses two subtypes and reduces this concern.
PICO (Intervention): Corticosteroids; Synthetic disease-modifying anti-rheumatic drugs (DMARDs); Biologic DMARDs | Literature scan, Key Informant | Corticosteroids are commonly used as first-line treatment for most cases of JIA. | Remove as a intervention, and include as a comparator | Intervention: DMARDs | This change reflects the standard of care and the literature. This does not significantly compromise fidelity to the original nomination. The principal dilemma relates to DMARDs and not corticosteroids; this makes them better suited as a comparator for DMARDs.
PICO (Outcome): Outcomes include looking at potential harms and benefits of various treatments | Literature scan, Key Informants, Local Experts | Specific outcomes are not included | Include relevant outcomes, and specify them in the key questions and PICO | - See refined KQs; - Outcome: Patient-centered outcomes (such as pain control, clinical remission, and quality of life); intermediate outcomes (laboratory measure of inflammation, number of joints with limited range of motion); and adverse effects of treatment. | Distinguishing between patient-centered outcomes and intermediate outcomes elucidates the underlying relationship of the outcomes and the logic of the SR
Nominated KQ | Literature scan, key informant, local experts | The outcomes listed do not reflect the clinical logic typically seen in AFs and refined KQs. The nominated topic places patient-centered outcomes (e.g., patient functioning) and intermediate outcomes (e.g., radiographic joint damage) in the same key question. | Formulate key questions specific to the outcome categories (patient-centered outcome; intermediate outcome). | - KQ: See refined KQ 1 (patient-centered outcomes) and KQ 2 (intermediate outcomes).; - AF: The relationship of the outcome categories is represented in the AF | Accuracy and research feasibility are improved by including specific outcomes in the KQ. Distinguishing patient-centered outcomes from intermediate outcomes elucidates the underlying relationship of the outcomes and the logic of the SR.
Nominated KQ | Literature scan | Many studies use ACR Pediatric 30, a validated composite measure of improvement of JIA. It includes patient –centered outcomes and intermediate measures. Some measures of the Peds 30 were included in the nominated materials. | Include mention of Peds 30 measure in the AF. | In the AF, asterisks (*) have been added to the outcomes that are constituents of the Peds 30 measure. | The literature scan provided added detail about relevant outcomes, including that part of the ACR Pediatric 30. This improves the accuracy and research feasibility of the review.

Appendix Figure B2 Example analytic framework

* Measures used in the “ACR Pediartic 30” definition of improvement

Note: CRP=C-reactive protein, DMARD= disease-modifying anti-rheumatic drug, ESR = erythrocyte sedimentation rate, KQ = key question, ROM=.range of motion

The analytic framework section depicts a flow diagram outlines the population, interventions and outcomes considered in the DMARDs review. This figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates how treatment of JIA in children with DMARDs versus intra-articular corticosteroids and NSAIDs may result in intermediate outcomes (e.g., changes in laboratory measures of inflammation, changes in the active joint count, or radiologically evident progression of disease) and/or long-term outcomes (e.g., clinical remission, changes in quality of life, changes in growth, and changes in development). In addition, adverse events may occur at any point after the treatment is received.

Key Questions
KQ1 Does treatment with any of a variety of disease-modifying anti-rheumatic drugs (DMARDs), alone or in combination, improve health outcomes (i.e. pain control; clinical remission; quality of life; parent/patient global assessment; mortality; function; or growth and development) compared with placebo, NSAIDs and/or corticosteroids, or other DMARDs?
KQ2 Does treatment with any of a variety of DMARDs, alone or in combination, improve other outcomes (i.e. active joint count; number of joints with limited ROM; laboratory measures of inflammation; physician global assessment; or radiographic change) compared with placebo, nonsteroidal anti-inflammatory drugs (NSAIDs) and/or corticosteroids, or other DMARDs?
KQ3 Is improvement with other outcomes associated with improvement in health outcomes?
KQ4 Does treatment with any of a variety of DMARDs, alone or in combination, result in additional troublesome or serious harms compared with placebo, NSAIDs and/or corticosteroids, or other DMARDs?
KQ5 How do the efficacy, effectiveness, safety or adverse effects of treatment with DMARDs differ between each of the various subtypes of juvenile idiopathic arthritis (JIA)?