# Abbreviations

A1c/HbA1c: Hemoglobin A1c or glycated hemoglobin level
AHRQ: Agency for Healthcare Research and Quality
EHC: Effective Health Care
EPC: Evidence-based Practice Center
PICOTS: Population, intervention, comparator, outcome, timing, and setting
SRC: Scientific Resource Center