# Materials and Methods

Three independent reviewers participated in the empirical testing conducted in this project. These reviewers work as full-time investigators in our Evidence-based Practice Center (EPC). They have extensive experience in the conduct of evidence-based medicine research (having participated in or led numerous systematic reviews with quality assessments over the past 5 years) and have undergone formal training in research methodologies (either with master’s and Ph.D. degrees or other types of postgraduate training).

Data extractions and analyses were conducted in three sequential exercises:

- Exercise 1: Quality assessment of randomized controlled trials (RCTs) based on the default quality item checklist used in EPC reports without further instruction.
- Exercise 2: Quality assessment of RCTs guided by explicit definitions of quality items.
- Exercise 3: Quality assessment of RCTs based on manuscripts stripped of identifying information, and performance of sensitivity analyses of quality items.

Data generated in each exercise were used to design and execute the subsequent one. The reviewers convened after the completion of each exercise, analyzed data, and discussed findings. Data collected in Exercise 1 were used to address questions 1, 2, and 3 (see above); Exercise 2 for questions 1–5; and Exercise 3 for question 6.

The RCTs selected for this exercise had been included in a comparative effectiveness review (CER) on sleep apnea. Those RCTs addressing the Key Question of efficacy of interventions for the treatment of sleep apnea and for the outcome of the Epworth Sleepiness Scale were considered eligible. Two sets of RCTs evaluating two different treatment comparisons were selected for inclusion: 11 RCTs on continuous positive airway pressure (CPAP) versus mandibular advancement devices were used for Exercise 1; a separate set of 11 RCTs comparing fixed CPAP versus auto-titrated CPAP were used in Exercises 2 and 3.

A detailed description of the methodology used in each exercise is provided below.

## Exercise 1 Quality Assessment of RCTs Based on the Default Quality Item Checklist Used in EPC Reports Without Further Instruction (Answers Questions 1, 2, and 3)

In the first exercise, we aimed to capture the baseline variations in quality assessments between independent reviewers. Thus, the reviewers assessed the quality of an initial set of RCTs with no additional guidance beyond the customary practice at this EPC (see below) regarding study quality assessment. This exercise was designed to mirror the pilot quality assessments process during the initial phases of conducting an EPC evidence report and before reaching consensus on the content-specific considerations for quality assessments on a given topic.

In Exercise 1, the initial set of 11 RCTs was subjected to a formal quality assessment process, conducted in parallel by the three independent reviewers. The reviewers had participated in the CER of sleep apnea but had little or no recollection of these particular studies. Thus, their background knowledge of the topic was considered to be similar. The reviewers were blinded to other reviewers’ assessments of these studies.

In this process, we applied the quality item checklist routinely used by our EPC (Table 1). In addition to a set of essential items, this checklist was also customized to include additional quality items germane to the topics at hand. The essential items represent both methodological and reporting variables that point to the quality of a study, as per the AHRQ methods reference guide. The possible responses to each item were: “Yes,” “No,” “Not-applicable” or “Not defined.” For the purposes of this project, all negative responses were considered equivalent. The reviewers used the EPC system for rating the quality of studies (A, good; B, fair; C, poor) according to the AHRQ methods reference guide (Table 2).12 These summary judgments of study quality are not based on a mathematical formula or a decision rule on the exact number of quality items satisfied. Instead, the reviewers perform a global assessment of each study’s risk of bias guided by the quality item checklist and other unmeasured considerations.

Table 1 Quality item checklist

Quality Item | Possible Responses
Appropriate randomization technique | Y, N, Nd, NA
Allocation concealment | Y, N, Nd, NA
Dropout rate <20 percent | Y, N
Blinded patient | Y, N, Nd
Blinded outcome assessment | Y, N, Nd
Intention to treat analysis | Y, N, Nd
Appropriate statistical analysis | Y, N
If multicenter, was this accounted for in analysis? | Y, N, NA
Were potential confounders properly accounted for? | Y, N, Nd, NA
Clear reporting with no discrepancies | Y, N
Were eligibility criteria clear? | Y, N
Was selection bias likely? | Y, N
Were interventions adequately described? | Y, N
Were the outcomes fully defined? | Y, N

Y = yes; N = No; Nd = Not defined; NA = Not-applicable

N must be ≥30 per intervention in a parallel RCT for quality to be A. Dropout must be <20 percent for quality to be A.

Table 2 Summary ratings of quality of individual studies according to the AHRQ methods guide

A: Good (low risk of bias) | These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; low dropout rate; and clear reporting of dropouts.
B: Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
C: Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information; or discrepancies in reporting.

In addition to his/her own relative assessment, each reviewer was asked to provide a narrative summary of his/her quality assessment thought process for each study, in which additional quality issues could be raised or the influential quality issues further emphasized. The definition of the influential quality item was that a change in the rating of the influential quality item would result in a change in overall rating of study quality. The reviewers’ assessments of individual items and the overall quality study ratings were compared; agreement/disagreement on individual quality items and concordance of overall study quality ratings were quantified. Items/ratings with unanimous agreement across reviewers were tabulated. Then the proportion of agreement was calculated as the number of studies in which each item was in agreement divided by the total number of studies. Items with common disagreements and large variations in the responses given by the three reviewers were considered as items with potentially subjective interpretation; alternatively, items with consistent agreements were considered to have an objective and straightforward interpretation.

## Exercise 2 Quality Assessment of RCTs Guided by Explicit Definitions of Quality Items (Answers Questions 1–5)

In the second exercise, quality assessments were performed in a second set of RCTs, guided by explicit quality item definitions. Our chief aim in this second exercise was not to estimate the impact of providing directions on achieving agreement in quality ratings. We chiefly aimed to determine those methodological or reporting components of the quality item checklist that are likely to have inconsistent assessments, regardless of whether instructions were provided. To put it differently, we were primarily interested in the residual variations across reviewers after removing all other variations through the use of standardized processes.

Following the completion of the first exercise of quality assessment, we collectively reviewed the results and narrative descriptions to gain a more in-depth appreciation of the factors that determined rating decisions. Furthermore, all additional issues that the reviewers raised in their narrative descriptions in exercise 1 were summarized and evaluated.

We then examined the individual quality items in further detail and drew up a list of all assessed quality items, providing explicit definitions for each (Table 3). These item definitions were developed based on previous literature reviews13,14 and consensus among the three reviewers with regards to the clinical context of the RCTs in question. No cognitive testing of these item definitions was done prior to their implementation (i.e., by examining with a questionnaire how the reviewers interpreted these definitions), since the reviewers reached consensus on the face validity of these definitions, which are commonly used in CERs conducted in our EPC. Thus, this phase of developing quality parameters and definitions mimics the initial stages in conducting a CER, when consensus among reviewers is reached on the quality parameters to be examined, following some pilot evaluations of studies.

Table 3 Explicit definitions of quality items

Item | Definition
Appropriate Randomization Technique | Y: Block randomization, permuted blocks, stratified randomization, central computer randomization N: No specification of method
Allocation Concealment | Y: Stated by study that allocation was concealed (face value), central computer randomization, masked medicine vials, opaque envelopes N: Tables, cards, plain envelopes, randomization by birth year or registration number (enabling prediction of randomization by investigators), quasi-randomization techniques, not specified
Dropout Rate <20 percent | [(N randomized) − (N analyzed)]/(N randomized) = <20 percent
Blinded Patient | Explicit statement
Blinded Outcome Assessment | Explicit statement
Intention to Treat Analysis | Even if ITT is mentioned, study checked for denominator=N randomized. If ≠, then ITT is not met.
Appropriate Statistical Analysis | Y: Multivariable model adjusting for confounders, interactions examined. Univariate analyses are acceptable if randomization is successful. For cross-over studies, assessment of order effects or treatment by period interactions. N: All other cases (for crossover studies, unpaired comparisons or pooling of observations)
If Multicenter, Was This Accounted For in Analysis? | Y: A “center effect” variable was included in the multivariable statistical model (adjustment) N: No adjustment for center effect, even if randomization was stratified by center
Were Potential Confounders Properly Accounted For? | Y: Adjustment in a multivariable statistical model N: No adjustment For RCTs, if there were baseline differences in the groups that could be confounders, were these examined? If not, reviewers were instructed to answer “N.” For RCTs with successful randomization, there may be no need for further adjustment, and the randomization has secured equal distribution of confounders between the study arms. Thus reviewers could answer “Y,” implying that the randomization process had taken care of confounding. For non-RCTs, adjustment is necessary and the above Y and N cases apply.
Clear Reporting of Results With No Discrepancies | Results easily extractable from figures, text or tables, with no discrepancies in the available information from these sources
Were Eligibility Criteria Clear? | Clear reporting of inclusion and exclusion criteria
Was Selection Bias Likely (if yes, explain below)? | For RCTs: Y: If significant baseline differences are present; if allocation was not concealed N: In all other cases For non-RCTs the answer is always “Y”
Were Interventions Adequately Described? | Clear reporting
Were the Outcomes Fully Defined? | Y: Clear reporting, specification of primary/secondary N: No specification of primary/secondary outcomes, lack of clear description of definitions

Y = yes; N = no; RCT = randomized controlled trial

Guided by these item definitions, quality assessments were performed on the second set of 11 RCTs. In this second set, we aimed to identify quality items with residual common disagreements among the reviewers. Items for which disagreements were resolved or reduced compared to the first set of RCTs would indicate that their assessment could be made more objective once adequate clarifications were provided to the reviewers. Conversely, items for which residual common disagreements were observed could be considered as unresponsive to the effort to reduce variations with the use of definitions; such items were considered to be indicative of quality attributes that were more subjective. We also examined the proportions of items that received a “Yes” response overall (i.e., specific item being satisfied) and stratified by: (1) studies with inter-reviewer concordance on the overall study rating, and (2) studies that received a “B” or a “C” quality rating. By comparing the proportions of “Yes” items (e.g., blinding) between these different groups of studies, we aimed to gain an appreciation of which items may have been influential in determining the overall study quality ratings.

## Exercise 3 Quality Assessment of RCTs Based on Manuscripts Stripped of Identifying Information, and Performance of Sensitivity Analyses of Quality Items (Answers Question 6)

In exercise 3, we utilized the data generated in exercise 2 to suggest the desirable sensitivity analyses based on the “influential” quality items that were amenable to modification. Then, a research assistant created deidentified text documents of these same RCTs that were used in exercise 2. Using text-editing software, a research assistant created plain text versions of the RCTs from exercise 2 with all information relating to the paper’s provenance (title, authors’ names, affiliations, address for correspondence, journal’s name or other specific formatting of a journal) removed. In these anonymized documents, the corresponding text in each study that would affect the assessment in an “influential” quality item was modified, with the reviewers blinded to these changes. Such changes could be either favorable or unfavorable, having the potential to upgrade or downgrade a study’s quality.

The RCTs were then subjected to a new round of quality assessments by the same three reviewers, and it was examined whether these modifications impacted study quality ratings. A “wash out” time (approximately 3 weeks) between the second and third exercise was allowed to pass such that the three reviewers would have little or no recollections of their prior assessments of these RCTs (note that the results reported in the Results chapter affirmed this supposition).

Given the small sample sizes in these exercises, results obtained in this phase of the project were analyzed qualitatively and without any formal statistical comparisons.