# Background

Critical appraisal of individual studies with a formal summary judgment for methodological quality and subsequent assessment of the strength of a body of evidence addressing a specific question are essential activities of conducting comparative effectiveness reviews (CERs). A study’s “quality” can be defined as the extent to which all aspects of the study’s design and conduct can be shown to protect against systematic bias, nonsystematic bias, and inferential error.1 The purpose of assessing the quality of individual studies is to inform a judgment about the validity of their results. Thus, a quality assessment of a study can be thought of as the process of assessing the risk that the results reflect bias in study design or execution rather than the true effect of the interventions under study. In the context of CERs, the term “quality” can be used interchangeably with the term “risk of bias,” which represents a recent evolution in evidence synthesis terminology.2–4

Over the past three decades, numerous systems for rating the quality of randomized controlled trials have been proposed.5 Such rating systems can be categorized as scales with numerical summary scores, checklists, or checklists with a summary judgment. However, empirical studies have found that there is no single reliable way to assess quality and have generally shown that summary numerical scores do not explain heterogeneity in effect estimates between individual studies, and thus are not recommended.6,7

For quality assessment of primary studies included in CERs, the Agency for Healthcare Research and Quality (AHRQ) has published a Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews to be used by researchers from Evidence-based Practice Centers (EPCs) when conducting CERs.8 The AHRQ methods guide proposes a checklist of quality item indicators to help substantiate an overall summary judgment for the quality of a study (rated as good or low risk of bias; fair; poor or high risk of bias). Although a set of methodological items is taken into consideration for reaching these summary judgments, there is no explicit decision rule on how to weigh and combine the items into one overall summary judgment of quality rating. The final decision on the overall summary judgment of quality rating is largely at the discretion of the individual reviewer.

Uncertainty concerning the optimal approach of quality assessments has given rise to wide variations in practice. Multiple quality tools have been developed, and empirical studies show that there is little agreement in the quality assessments of the same study using different tools.4,9 Thus, the overall conclusion of a particular CER could be dependent on which instrument is used for assessing the validity of a study’s results.

In addition to the variations in different quality assessment tools, the subjective nature of many quality measures engenders inconsistencies in the assessments by different reviewers even when the same tool is applied. Duplicate, reconciled appraisals by independent reviewers are a common method used to mitigate these inconsistencies. However, this process may merely mask the underlying variations in study quality assessment.

Similarly, conclusions drawn from systematic reviews must rely on evaluations of the collective strength of the underlying evidence,10,11 and while different methods of assessing the strength of a body of evidence exist, they again must inevitably rely on the quality of the individual studies reviewed. Variations in assessed study quality (and in turn the assessed strength of a particular body of evidence) may therefore impact conclusions from CERs and the resulting clinical decisionmaking.

For these reasons, a well-defined and transparent methodology to evaluate the robustness of quality assessments is critical for the interpretation of systematic reviews as well as the larger CER process. For a quality rating to be robust, the method for assigning a rating must consider the uncertainties of assessing study quality. In addition, the assumptions made in the interpretation of data should be made explicit and subject to sensitivity analyses to assess the stability of the conclusions and the overall study rating. Finally, the thought process in determining the final rating should be made transparent so readers can better appreciate a review’s conclusion.

In an effort to develop such a methodology, we completed the first phase of a project that aimed to examine the extent and potential sources of inter- and intra-rater variations in quality assessments, as conducted in our EPC. In subsequent phases of this project, we propose to engage other EPCs to apply the methodological framework developed in the initial phase and gather additional data to verify our findings. The additional data would allow us to examine sources of variation in quality rating across individuals and EPCs. We also propose to develop a software tool to facilitate collecting and analyzing such data and to present quality assessment information to users of CERs. Findings from this project will help promote a transparent and robust process for the evaluation of the quality of individual studies and the assignment of a grade for overall strength of available evidence for use in the compilation of comprehensive evidence reports.