# Results

Without correction for publication bias, the performance of the estimated parameters in the usual fixed effect (FE) and random effects (RE) metaregression models largely depends, rather unsurprisingly of course, on whether or not publication bias exists, although to a lesser extent, the relative performance of the FE and RE models also depends on the magnitude of between-study variability (τ^2^).

In the absence of publication bias (i.e., with zero missing studies), the absolute biases of the estimated intercept (Appendix Table E1) and slope (Appendix Table E7) were both negligible, independent of the true value of the slope parameter, the magnitude of between-study variability, sample size (from 25 to 65), and model assumptions concerning random variability (FE or RE). In contrast, still in the absence of publication bias, the coverage probabilities of the confidence intervals around the estimated intercept (Appendix Table E2) and slope (Appendix Table E8) were mixed. The coverage probabilities achieved the nominal level (95 percent) in the absence of between-study variability (τ^2^ = 0), independent of both sample size and model assumptions (FE or RE). However, with between-study variability (τ^2^ > 0), coverage probabilities of intervals around both the estimated slope and intercept rapidly decreased with increasing between-study variability in the FE model, but were stable, albeit modestly below nominal level, with increasing between-study variability in the RE model. In all instances, associations of coverage probabilities with simulation parameters were independent of the true value of the slope parameter. Finally, still in the absence of publication bias, the relative bias of the estimated slope parameter (Appendix Table E13) was mixed, although only as a function of the true value of the slope parameter. When the true value of the slope was 0.049, the relative bias of the slope parameter was generally non-negligible, although without discernible patterns with respect to other simulation parameters. As the true value of the slope increased, the relative bias of the slope parameter typically decreased, such that when the true value of the slope was 0.444, relative bias was, in fact, negligible. Much of this relative bias is symptomatic of the metric itself, since even a small absolute bias may be a quite large relative bias when the true value of the parameter in question is in the neighborhood of zero.

Without correction for publication bias in spite of the presence of such bias, the performance of the estimated intercept and slope parameters, along with associated confidence intervals, was much different. Absolute bias of the estimated intercept was positive (Appendix Table E1). Absolute bias increased as the number of missing studies increased (from 5 to 10), as between-study variability increased, and as the true value of the slope parameter increased. Absolute bias decreased as the sample size increased. Bias was largely independent of model assumptions (FE or RE), with only a modest increase in the RE vs. FE model when τ^2^ = 0, and a modest decrease in the RE versus FE model when τ^2^ > 0. The absolute bias of the estimate slope parameter, in contrast, was negative (Appendix Table E7). Absolute bias of the estimated slope also increased in (absolute) magnitude as the number of missing studies increased, as between-study variability increased, and as the true value of the slope parameter increased, while bias decreased as sample size grew larger. The coverage probabilities of the confidence intervals around the estimated intercept (Appendix Table E2) and slope (Appendix Table E8) decreased, relative to probabilities in the absence of publication bias. Coverage probabilities decreased as the number of missing studies increased (particularly with 10 missing studies), as between-study variability increased, as the true value of the slope increased, and interestingly, even as the sample size increased. Decreases were equally apparent in the both the FE and RE models. Finally, the relative bias of the estimate slope (Appendix Table E13) typically increased, compared to the relative bias in the absence of publication bias. Associations of relative bias with simulation parameters mirrored the above associations of absolute bias in the estimated slope with simulation parameters.

With correction for publication bias, via imputation of k = R or k = L studies, as estimated and identified from the modified trim and fill algorithm, the performance of the estimated intercept and slope parameters, along with associated confidence intervals, was mixed, as a function of whether or not publication bias was actually present. In the absence of publication bias, the imputation of k studies actually introduced negative absolute bias in the estimated intercept (Appendix Tables E2 and E3). This bias grew in (absolute) magnitude as the true value of the slope increased and as between-study variability increased. This bias was largely independent of sample size, but was clearly larger in the RE versus FE model, independent of the magnitude of τ^2^. Conversely, but still in the absence of publication bias, imputation of k studies introduced non-negative absolute bias in the estimated slope (Appendix Tables E8 and E9). In the FE model, bias was generally negligible, but in the RE model, bias was generally positive, relatively more so as the true value of the slope increased. As with the estimated intercept, the absolute bias in the estimated slope was larger in the RE versus FE model. The coverage probabilities of the confidence intervals around the estimated intercept (Appendix Tables E5 and E6) and slope (Appendix Tables E11 and E12) parameters were practically unchanged, with only very modest degradation, relative to a lack of correction for publication bias. Finally, patterns in the relative bias of the estimated slope parameter (Appendix Tables E14 and E15), with correction for publication bias despite the absence of such bias, generally mirrored corresponding patterns in the absolute bias of the estimated slope parameter. In particular, for larger true values of the slope parameter, relative bias in the estimated slope was negligible in the FE model, but almost always positive in the RE model, with increasing bias as between-study variability increased.

With correction for publication bias in the absence of such bias, the performance of estimated parameters, and associated confidence intervals, was generally superior with imputation of k = R vs. k = L studies. In particular, with imputation of R versus L studies, absolute and relative biases in the estimated intercept and slope parameters were generally smaller and corresponding coverage probabilities were generally larger.

When publication bias actually existed, the imputation of k studies resulted in meaningful, albeit incomplete correction of bias in estimated model parameters induced by publication bias. The absolute bias of the estimated intercept (Appendix Tables E2 and E3) and slope (Appendix Tables E8 and E9) parameters was reduced via application of modified trim. Absolute bias in the estimated intercept parameter was mostly eliminated, with five missing studies from any sample size given small τ^2^, from sample size ≥35 given medium τ^2^, and from sample size ≥45 with large τ^2^, all through fitting of an FE model. Bias was also mostly eliminated with 10 missing studies from sample size ≥45 given small τ^2^ and from sample size 65 given medium τ^2^, but non-trivial bias remained with 10 missing studies and large τ^2^, again all through fitting of an FE model. Generally, the absolute bias in the estimated intercept was further reduced through fitting of an RE model, even independent of the magnitude of τ^2^, so much so that absolute bias was largely eliminated with 10 missing studies from sample size 65 in sets of studies with large between-study variability. The absolute bias of the slope parameter exhibited similar improvement, with analogous associations with simulation parameters. In particular, with 5 missing studies, bias was largely eliminated only as sample size increased, given increasing levels of between-study variability, while with 10 missing studies, bias was eliminated only with even larger sample size, given commensurate between-study variability. Again, bias was further reduced through fitting of an RE model, relative to fitting of an FE model. The relative bias of the estimated slope parameter (Appendix Tables E14 and E15) mirrored these trends. However, the relative bias metric better illuminates the fact that with a relatively large proportion of missing studies attributable to publication bias and substantial between-study variability (beyond that accounted by the metaregression model), nontrivial negative relative bias remains in the estimated slope. Coverage probabilities of the confidence intervals around the estimated intercept (Appendix Tables E5 and E6) and slope (Appendix Tables E11 and E12) were mixed, after correction for publication bias. In general, coverage probabilities of FE-model-derived intervals around the estimated intercept ranged from unchanged to slightly greater, relative to a lack of correction for publication bias. Improvements were seen, unsurprisingly, when τ^2^ = 0. However, all coverage probabilities of FE-model-derived intervals were below nominal level, particularly as between-study variability increased. Corresponding probabilities were much closer to nominal level with intervals derived from RE models. Interestingly however, coverage probabilities were modestly smaller with correction for publication bias than without such correction when the proportion of missing studies was low, although coverage probabilities were larger, as may be expected, when that proportion was high.

Throughout all scenarios in which the modified trim and fill algorithm was applied to sets of studies in which publication bias, in fact, existed, the imputation of k = R studies was generally superior to the imputation of k = L studies. Absolute and relative biases in model parameters were generally smaller, although coverage probabilities were often comparable.

Some of this difference can likely be attributed to the mean values of k. Mean values of k when k = R (Appendix Table E16) and k = L (Appendix Table E17) illustrate this. When k = R, the estimated number, k, of missing studies tends to exhibit good properties. It remains low in the absence of publication bias, typically exceeding one only with substantial between-study variability. It typically increases as the number of missing studies increases, but does not rapidly increase as sample size increases. However, when the proportion of missing studies is large (e.g., 10 studies from sample size 25), the estimated number of missing studies is badly biased downward. In contrast, when k = L, the estimated number of missing studies tends to exhibit less desirable properties. In the absence of publication bias, k typically increases as sample size increases, and with large between-study variability, overestimates the number of missing studies. When publication bias does exist, the estimated number of missing studies appears to increase rapidly with sample size, even with a given number of missing studies, but nonetheless remains negatively biased when 10 studies are missing, largely independent of the proportion of missing studies.

In Appendix Tables E1 through E17, we display simulation results from the one-dimensional variant of the modified trim and fill algorithm. In Appendix Tables E18 through E34, we display analogous results from the two-dimensional variant of the algorithm. In this variant, unlike in the former, a random effects metaregression model, with both an intercept and a slope parameter, is fit to the data during the iterative phase of the algorithm, during which k is estimated; in the former, only an intercept is included in the model that is fit during the iterative phase. Patterns associated with the simulation parameters are entirely analogous in this variant. Notably, however, all measures of bias in the estimated slope parameter indicate relatively poorer performance, with much larger relative bias, given a high proportion of missing studies and medium to high between-study variability.

## Example

We consider here data from 19 randomized studies examining the hypothesis that teachers' expectations influence students' IQ intelligence test scores.2 In each study, students were randomly assigned either to an experimental, “expectancy induction” group, or to a control group. Teachers of students in the experimental group were led to believe that their students were “likely to experience substantial intellectual growth.” The effect analyzed here is the standardized mean difference between the study groups.

The authors hypothesized that the magnitude of the response variable might be related to the length of time that the teacher and student were in contact prior to the expectancy induction. For instance, teachers who had accumulated more contact with students prior to the start of the study were expected to be less vulnerable to induction. Thus, amount of prior contact was categorized into two groups: contact for one week or less (i.e., the low-contact group) and contact for more than one week (i.e., the high-contact group). This variable is the study-level covariate used in the modified trim and fill algorithm.

In a metaregression ignoring the possibility of publication bias, the predicted mean response from a fixed effect model was Y = 0.349 – 0.371 * I [high-contact group], where I [high-contact group] is an indicator variable that equals 1 if a study is in the high-contact group, and equals zero if a study is in the low-contact group. In the model, the estimated intercept is significantly different from zero (95 percent confidence interval (CI): 0.19, 0.51; p <0.01), and so is the estimated slope (95 percent CI: -0.55, -0.20; p <0.01). A test of whether between-study variability was equal to zero versus greater than zero, given adjustment for heterogeneity induced by contact group, was nonsignificant (X^2^ = 16.8, df = 17, p = 0.47), suggesting that a random effects model was unnecessary. Perhaps of greater interest are the predicted means of the response variable in each contact group. In the low-contact group, the predicted mean response was 0.35 (95 percent CI: 0.19, 0.51; p < 0.01). In contrast, in the high-contact group, the predicted mean response was -0.021 (95 percent CI: -0.102, 0.059; p = 0.60). Thus, there was a significant, positive effect of expectancy induction in studies in the low-contact group, but a nonsignificant, modestly negative effect of induction in studies in the high-contact group.

With application of the one-dimensional variant of the modified trim and fill algorithm, and with k = R missing studies, there is evidence of funnel plot asymmetry, with estimated R = 2. Both of the missing studies are estimated to be in the high-contact group. Interestingly, after imputation of this pair of studies, there is some evidence of between-study heterogeneity, even with adjustment for contact group (X^2^ = 31.4, df = 17, p = 0.04). Thus, unlike above, a random effects model is likely appropriate here. In a metaregression with imputation of missing studies, the predicted mean response from a random effects model was Y = 0.368 – 0.450 * I [high-contract group]. In the model, both the estimated intercept (95 percent CI: 0.16, 0.54; p <0.01) and the estimated slope (95 percent CI: -0.60, -0.15; p <0.01) remained significantly different from 0. In the low-contact group, the predicted mean response was 0.37 (95 percent CI: 0.16, 0.54; p <0.01), quite similar to the earlier analysis, unsurprisingly, since the trim and fill algorithm estimated no missing studies in this group. However, in the high-contact group, the predicted mean response was -0.082 (95 percent CI: -0.20, 0.034; p = 0.16). Therefore, while there was persistent evidence of a positive effect of expectancy induction in the studies in the low-contact group, there was also evidence, albeit nonsignificant, of an opposite, negative effect in the high-contact group. As an example, this finding is compatible with the hypothesis that expectancy induction in teachers with lengthy contact with students may encourage complacency, resulting in lower IQ intelligence test scores.

Figure 3 gives a funnel plot of the teacher expectancy studies, using different symbols for the low- and high-contact groups. The imputed studies are shown as open symbols. In Figure 4, the residuals after fitting the metaregression model to the data are shown. Evidently, publication bias may have resulted in censoring of two studies in the high-contact group, both with very negative findings.

Figure 3 Funnel plot of the teacher expectancy data, showing imputed studies

Figure 4 Funnel plot of the residuals of the standardized mean differences, showing imputed data

In Figure 4, the residuals after fitting the metaregression model to the data are shown. Evidently, publication bias may have resulted in censoring of two studies in the high-contact group, both with very negative findings.

A scatter-plot with all relevant studies, along with the fitted regression lines both before and after correction for publication bias, is shown in Figure 5. Addition of these studies to the observed studies results in a more negative slope in the fitted regression line.

Figure 5 Application of the modified Trim and Fill algorithm to the teacher expectancy data

A scatter-plot with all relevant studies, along with the fitted regression lines both before and after correction for publication bias, is shown in Figure 5. Addition of these studies to the observed studies results in a more negative slope in the fitted regression line.

Finally of note, with k = L, the modified trim and fill algorithm estimated L = 3. This resulted in a slightly more negatively sloped line than k = R, but the quantitative difference in conclusions regarding the high-contact group was trivial.