# References

1 Duval S, Tweedie R. “Trim and fill” method of accounting for publication bias in meta-analysis. Journal of the American Statistical Association. 2000;95(449):89-98.
2 Raudenbush SW. Magnitude of teacher expectancy effects on pupil IQ as a function of the credibility of expectancy induction. Journal of Educational Psychology. 1984;76:85-97.
3 R Development Core Team. R: A language and environment for statistical computing, reference index version 2.8.1. Vienna, Austria. R Foundation for Statistical Computing. Vienna, Austria. 2005. Available at: www.R-project.org.
4 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. Jun. 2000;56(2):455-63. [pmid: 10877304].
5 Dickersin K, Min Y, Meinert C. Factors influencing publication of research results. JAMA. 1992;267:374-8. [pmid: 1727960].
6 Easterbrook P, Berlin J, Gopalan R, et al. Publication bias in clinical research. Lancet. 1991;337:867-72. [pmid: 1672966].
7 British Medical Journal Editorial Staff. The editor regrets…(editorial). British Medical Journal. 1983;280:508.
8 Glass GV. Primary, secondary, and meta-analysis of research. Educational Researcher. 1976;5:3-8.
9 Light RJ, Pillemer DB. The Science of Reviewing Research. Cambridge, MA. Harvard University Press. 1984;1.
10 Begg CB, Berlin JA. Publication bias: A problem in interpreting medical data. Journal of the Royal Statistical Society. A. 1988;151:419-63.
11 Sterne JAC, Gravaghan D, Egger M. Publication and related bias in meta-analysis: Power of statistical tests and prevalence in the literature. Journal of Clinical Epidemiology. 2000;53:1119-29. [pmid: 11106885].
12 Egger M, Smith GD, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
13 Begg CB, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. Dec. 1994;50(4):1088-1101. [pmid: 7786990].
14 Vevea JL, Hedges LV. A general linear model for estimating effect size in the presence of publication bias. Psychometrika. 1995;60:419-35.
15 Hedges LV, Vevea J. Selection method approaches to publication bias. Rothstein H, Sutton A, Borenstein M, editors. Publication bias in meta-analysis. New York. John Wiley. 2005:145-74.
16 Candelise L, Ciccone A. Gangliosides for acute ischaemic stroke (Cochrane Review), The Cochrane Library. Chichester, UK. John Wiley & Sons, Ltd. 1998;(1).
17 Peters JL, Sutton AJ, Jones DR, et al. Performance of the trim and fill method in the presence of publication bias and between-study heterogeneity. Statistics in Medicine. 2007;26(25):4544-62. [pmid: 17476644].
18 Terrin N, Schmid CH, Lau J, et al. Adjusting for publication bias in the presence of heterogeneity. Statistics in Medicine. 2003;22:2113-26. [pmid: 12820277].