# Methods

We conducted a simulation study, using a factorial design for the simulation parameters, to assess the performance of the newly developed “modified” trim and the fill algorithm. We define the modified trim and fill algorithm as the original trim and fill algorithm adapted to a two-dimensional metaregression.

For completeness, we present a brief description of the original trim and fill method, as described fully in Duval and Tweedie.1,4

## The “Original” Trim and Fill Method

The trim and fill method is a simple rank-based augmentation technique to formalize the use of a funnel plot. The method can be used to estimate the number of missing studies and, more importantly, to provide an estimate of the estimate of the “treatment” effect by adjusting for potential publication bias in a meta-analysis. The mechanics of the approach are displayed in Figure 1, using a meta-analysis of the effect of gangliosides on mortality from ischemic stroke.16 Figure 1 shows the observed studies as filled circles, with the open circles denoting the imputed missing studies. Note that the “funnel” is much more visually symmetric with the inclusion of the imputed data. The bottom panel of Figure 1 gives the odds ratios (ORs) and their 95 percent confidence intervals before and after allowing for publication bias, on the OR scale.

Figure 1 Trim and fill applied to a meta-analysis of the effect of gangliosides on mortality from ischemic stroke

The mechanics of the trim and fill approach are displayed in Figure 1, using a meta-analysis of the effect of gangliosides on mortality from ischemic stroke. The top panel shows the observed studies as filled circles, with the open circles denoting the imputed missing studies. The “funnel” is much more visually symmetric with the inclusion of the imputed data. The bottom panel gives the odds ratios (ORs) and their 95 percent confidence intervals before and after allowing for publication bias, on the OR scale.

The key assumption of the method is that it is the most extreme negative studies which have not been published. Three easily calculated estimators for the number of missing studies, R, L, and Q, have been derived based on method of moment considerations.

## The Modified Trim and Fill Algorithm

### Generation of Simulated Meta-Analytic Data

We simulated metaregression data under a variety of conditions. Simulated data were generated from a hierarchical model. For i = 1, 2, …, n, where n is the number of studies, both published and unpublished, we had:

X_1,i_ ~ f (X_1_),

θ_i_ | X_1,i_, β ~ N( β_0_ + β_1_ * X_1,i_, τ^2^),

σ_i_ ~ Gamma(3, 1/9),

Y_i_ | θ_i_, σ_i_ ~ N(θ_i_, σ_i_^2^),

where the parameters β_0_, β_1_, and τ^2^ were pre-specified.

We varied the following parameters in our simulation:

1. Sample size. We set n = 25, 35, 45, 55, and 65.
2. Distribution of X_1_. We set f (x) = (1/2)^x^(1/2)^1-x^, for x = 0, 1 (i.e., Bernoulli), and f (x) = 1, for 0 < x < 1.
3. Slope parameter. We set β_1_ = 4/81, 2/27, 4/27, 8/27, and 12/27. (We set β_0_ = 0 in all simulations.)
4. Between-study variability. We set τ^2^ = 0, 4/81, 4/27, and 4/9.
5. Number of missing studies. We set k = 0, 5, and 10.
6. Dimension of the metaregression model during the iterative portion of the algorithm. We set the dimension d = 1 and 2.

### Two Variants of the Algorithm

From a sample of n studies, k studies were censored. We defined r_i_ as the rank of Y_i_, and censored those studies with rank r_1_, r_2_, …, r_k_. Therefore, censoring resulted in an “observed” sample of m = n − k studies.

We fit both a fixed effect (FE) and random effects (RE), two-dimensional metaregression model to each observed sample. Then, we proceeded to apply the following adaptation of the trim and fill algorithm:

1. Fit an FE model to the observed sample: for i = 1, 2, …, m,
  Y_i_ = β_0_ + β_1_ * X_1,i_ + e_i_,
  where e_i_ ∼ N(0, σ_i_^2^).
  Denote the estimates of (β_0_, β_1_) by [β]^(1)^ = ([β_0_]^(1)^, [β_1_]^(1)^).
2. Calculate centered values from the fitted FE model: for i = 1, 2, ..., m,
  Y_i_^(1)^ = Y_i_ - ([β_0_] + [β_1_] * X_1,i_).
  Estimate k ^(1)^, the number of missing studies, using one of the three usual estimators, applied to the set {Y_i_^(1)^}, i = 1, 2, …, m:
  R = γ^*^ - 1,
  L = [4 * T_m_ – m * (m + 1)] / [2 * m – 1],
  Q = m – 1/2 – √ [2 * m^2^ – 4 * T_m_ + 1/4],
  where γ* and T_m_ are defined in the usual manner.4
3. Remove those studies with the k^(1)^ largest values of {Y_i_^(1)^} from the observed sample. Fit an FE model to the reduced sample of m - k^(1)^ studies, and calculate centered values, based upon the updated estimate [β]^(2)^ = ([β_0_]^(2)^, [β_1_]^(2)^):
  Y_i_^(2)^ = Y_i_ - [β_0_]^(2)^ + [β_1_]^(2)^ * X_1, i_).
  Estimate k ^(2)^ from the set {Y_i_^(2)^}, i = 1, 2, ..., m.
4. Continue until an iteration J where k^(J)^ = k^(J - 1)^ ≡ [k].
  Set [β] = ([β_0_], ([β_1_] = ([β_0_]^(J)^), [β_1_]^(J)^), and for j = 1, 2, ..., [k], define the triplet Z_j_:
  Z_j_ = (Z_1j_, Z_2j_, Z_3j_) = (Y_h_^(J)^, σ_h_, X_1, h_),
  where h is the index value such that the rank of Y_h_^(J)^ equals m - j + 1.
5. As a final step, augment the observed sample with [k] studies:
  X_1,J_ = 2 * midrange {X_1_} - Z_3,j_,
  σ_j_ = Z_2,j_,
  Y_j_ = [β_0_] + [β_1_] * X_1,j_ - Z_1,j_,
  for j = 1, 2, ..., [k], where midrange{X_1_} is the mid-range of X_1_, which may be either estimated or specified by the analyst.
  Figure 2 is a simple visual illustration of how Step 5 is implemented in the algorithm. Mid-range estimates include the maximum likelihood estimate (MLE) = [min(X_1_) + max(X_1_)]/2, or the method of moments estimate (MOM) = sample mean of X_1_. The user may also specify a mid-range, typically taken as the mean of user-specified minimum and maximum values for the covariate (e.g., 0 and 1, for a dichotomous X_1_).
6. In a metaregression model with covariate X_1_, analyze the set of m + [k studies, with either an FE model or an RE model.

Figure 2 Augmentation using the modified trim and fill algorithm

Figure 2 is a simple visual illustration of how Step 5 is implemented in the algorithm. Mid-range estimates include the maximum likelihood estimate = [min(X1) + max(X1)] / 2, or the method of moments estimate = sample mean of X1. The user may also specify a midrange, typically taken as the mean of user-specified minimum and maximum values for the covariate (e.g., 0 and 1, for a dichotomous X1).

As a variant on the above algorithm, we also considered fitting only a one-dimensional metaregression model during the iterative portion of the algorithm:

1. Fit an FE model to the observed sample: for i = 1, 2, ..., m,
  Y_i_ = β_0_ + e_i_,
  where e_i_ ∼ N(0, σ_i_^2^0.
  Denote the estimates of (β_0_) by [β]^(1)^ = ([β_0_]^(1)^).
2. Calculate centered values from the fitted FE model: for i = 1, 2, ..., m,
  Y_i_^(1)^ = Y_i_ - [β_0_].
  Estimate k ^(1)^, the number of missing studies, using one of the three usual estimators, applied to the set {Y_i_^(1)^}, i = 1, 2, …, m:
  R = γ^*^ - 1,
  L = [4 * T_m_ – m * (m + 1)] / [2 * m – 1],
  Q = m – 1/2 – √ [2 * m^2^ – 4 * T_m_ + 1/4],
  where γ* and T_m_ are defined in the usual manner.4
3. Remove those studies with the k ^(1)^ largest values of {Y_i_^(1)^} from the observed sample. Fit an FE model to the reduced sample of m - k^(1)^ studies, and calculate centered values, based upon the updated estimate [β]^(2)^ = ([β_0_]^(2)^):
  Y_i_^(2)^ = Y_i_ - [β_0_]^(2)^.
  Estimate k ^(2)^ from the set {Y_i_^(2)^}, i = 1, 2, ..., m.
4. Continue until an iteration J where k^(J)^ = k^(J^ ^- 1)^ ≡ [k].
  Set [β] = ([β_0_] = ([β_0_]^(J)^), and for j = 1, 2, ..., [k], define the triplet Z_j_:
  Z_j_ = (Z_1j_, Z_2j_, Z_3j_) = (Y_h_^(J)^, σ_h_, X_1, h_),
  where h is the index value such that the rank of Y_h_^(J)^ equals m - j + 1.
5. As a final step, augment the observed sample with [k] studies:
  X_1,J_ = 2 * midrange {X_1_} - Z_3,j_,
  σ_j_ = Z_2,j_,
  Y_j_ = [β_0_] + [β_1_] * X_1,j_ - Z_1,j_,
  for j = 1, 2, ..., [k], where midrange{X_1_} is the mid-range of X_1_, which may be either estimated or specified by the analyst.
  Figure 2 is a simple visual illustration of how Step 5 is implemented in the algorithm. Mid-range estimates include the maximum likelihood estimate (MLE) = [min(X_1_) + max(X_1_)]/2, or the method of moments estimate (MOM) = sample mean of X_1_. The user may also specify a mid-range, typically taken as the mean of user-specified minimum and maximum values for the covariate (e.g., 0 and 1, for a dichotomous X_1_).
6. In a metaregression model with covariate X_1_, analyze the set of m = [k] studies, with either an FE model or an RE model.

For each set of parameters, we ran 5,000 iterations. Within each iteration, we proceeded through the algorithm by estimating k with each of the three estimators, R, L, and Q.

We reported absolute bias and coverage probability for the regression parameters β_0_ and β_1_, along with relative bias for the parameter β_1_. We also report mean values for R, L, and Q, along with estimation failure rates for each of R, L, and Q. Estimation failure occurred when Q was inestimable, the estimate of k failed to converge within 100 steps, or if d = 2, when the estimate of k was equal to 1 at any point during the iterative portion of the algorithm.

All simulations were conducted in R, version 2.8.1.