# Further Work

In general, it appears that R is a superior estimator of k, in contrast to previous recommendations in support of L. It is unclear why this is the case here, and requires further investigation. In the future, we will investigate properties of the adapted algorithm in the presence of multiple covariates. This will allow a broader adjustment to be made, given covariate information and sufficient studies in each covariate profile. We will also assess inferential properties of predicted values from the metaregression.

We have written “trim.fill.regression,” a program (freely available) for the statistical software package, R. The program currently supports this adaptation of trim and fill for metaregression, but with just one covariate. Future versions will support multiple covariates. A beta version of the program can be requested from the authors. The software package Stata (StataCorp Inc, College Station, Tx) currently includes an implementation of the original trim and fill algorithm called metatrim. We intend for the modified algorithm to be incorporated into metatrim in collaboration with Stata developers, thus making the research much more widely accessible.

## Recommendation

We acknowledge that assessment for publication bias in the presence of heterogeneity requires considerable caution. Our recommendation when covariates are available is for the use of the modified trim and fill algorithm as a sensitivity analysis to the potential impact of publication bias.