# Acknowledgments

We would like to thank our reviewers, Dr. Michael Borenstein, Professor Larry Hedges, Dr. Alexander Sutton, and Dr. Norma Terrin, for reviewing and commenting on the draft. These reviewers and their affiliations are listed in Appendix A.

We also want to thank Marilyn Eells for her diligent editing and formatting of the report and Dr. Robert Kane for sharing his expertise in systematic reviews and his guidance throughout the project.