# Executive Summary

We have adapted the trim and fill algorithm,1 originally created to adjust for publication bias in meta-analysis, to its application in metaregression. Under this scenario, studies report heterogeneous effect estimates, at least in part attributable to systematic variation induced by differences in measured covariate(s) that summarize salient features of the individual studies. In other words, whereas typical meta-analysis models pool a set of effect estimates into a single summary measure of, for example, efficacy or risk, metaregression pools effect estimates into a summary measure that is a function of (i.e., conditional upon) the value of some exogenous covariate.

An example of this situation might be seen in a series of studies evaluating the association of teachers' expectations and students' IQ intelligence test scores. Raudenbush reported 19 studies, in which students were randomly allocated to either an experimental “expectancy induction group” or to a control group.2 Teachers of students in the experimental group were led to believe that their students were “likely to experience substantial intellectual growth.” Raudenbush also hypothesized that the magnitude of teacher expectancy effects might be related to the length of time that the teacher and student were in contact prior to the expectancy induction.2 The amount of prior contact can be categorized into two groups: (1) contact for one week or less, and (2) contact for more than one week. This two-level categorization of prior contact serves a binary covariate that may systematically induce variability in study effect estimates.

Heuristically, our adaptation of trim and fill to the metaregression situation functions in much the same fashion as the original algorithm. We start by fitting a metaregression model to the observed data. From that fitted model, we estimate the residuals of each observation (i.e., study) in the model. Then, from the set of residuals, we estimate the number of missing studies, k, with the same analytic tools proposed by Duval.1 We then trim those k studies with the largest residuals (in absolute terms), and re-estimate the metaregression model. Again, we estimate the residuals, and from there, the number of missing studies. This iterative loop proceeds until the estimate of k converges, which is indicated by the lack of a difference in estimates of k from one iterative step to the next. At this point, we fill the observed data set with k missing studies in the following manner. We identify those k studies with the largest absolute residuals (from the final fitted metaregression model to the trimmed data) and record the measured value of the exogenous covariate in those studies. For each of the k studies, we impute the “reflection,” where the reflection is taken across the midrange of the covariate and the final fitted metaregression model.

We evaluated the performance of this modified trim and fill algorithm under a wide variety of scenarios, using Monte Carlo simulation. In particular, we estimated the bias and coverage probability of estimated model parameters (e.g., intercept, slope) across ranges of the number of observed studies, the number of missing studies, the magnitude of between-study variability as induced by stochastic error, the magnitude of between-study variability as induced by the slope associated with the exogenous covariate, the distribution of the covariate (either binary or uniform), and the nature of the metaregression model applied during the iterative portion of trim and fill.

We showed that certain methodological choices—the nature of the metaregression model, the estimator of k—resulted in superior performance, and we illustrated that the adaptation of trim and fill does result in meaningful, albeit incomplete, reduction in the bias of estimated model parameters.

We created user-friendly software in R (version 2.8.1), an open-source statistical software package that is freely available for download at http://www.r-project.org/, that can be applied to existing datasets that are amenable to metaregression and suffer from suspected publication bias.3 This software reports metaregression estimates from both fixed-effects and random-effects models, both before and after application of trim and fill to the set of observed studies. We have also developed documentation for the software, and code for an example dataset.

We recommend the use of the modified trim and fill algorithm as a form of sensitivity analysis in the case where both heterogeneity and publication bias may play a role.