# Discussion

We have developed a new generalized trim and fill algorithm for analyzing heterogeneity and publication bias simultaneously in a meta-analysis. Since this report focuses on the development of a new method, we did not explicitly discuss investigation of the sources of heterogeneity per se. Naturally, elucidation of sources of heterogeneity may explain at least some of the funnel plot asymmetry, and may even obviate the need for adjustment for potential publication bias. The more typical situation arises where we do not have enough information to identify all of the sources for heterogeneity, or we are unable to remove all of the heterogeneity even when sources can be identified. Another issue is that metaregression methods require a minimal amount of studies—some say at least 10 per covariate—and this is not often the case in the medical literature.

In the simulation studies of Peters et al17 and Terrin et al,18 only unexplainable between-study heterogeneity was induced. Until now, there has been very little research into assessment of publication bias in the presence of explainable between-study heterogeneity. It may sometimes be the case that study-level covariates can explain some of the heterogeneity in a meta-analysis, which, although complicating the assessment of publication bias, is now addressable via the modified algorithm we have presented here.

We assessed the performance of the algorithm with simulation techniques and applied it to data from a set of 19 randomized studies examining the hypothesis that teachers' expectations influence students' intelligence test scores. We found that bias and coverage probability improved as the number of studies increased, varying from 25 to 65 component studies in the meta-analysis. The R estimator outperforms both L and Q from the original trim and fill method. Performance declined in the presence of large heterogeneity, with between-study variability varied from an intraclass coefficient (ICC) of 0 to 0.75, but substantial bias reduction still obtained. Two algorithm variants were developed, with the simpler one-dimensional version performing slightly better than the two-dimensional. We caution, however, that the one-dimensional variant may not be superior in all instances.

In general, the simulations show that estimation of the number of missing studies k is better using the R estimator, especially when between-study variability exceeds zero. The Q estimator should not be used to estimate k. Performance of the one-dimensional variant of the algorithm is superior to the two-dimensional version.