# Tables

Table E1 Absolute bias in the estimated intercept, with no correction for publication bias (from 1-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | 0.001 | 0.001 | 0.000 | 0.001 | -0.001 | 0.001 | 0.001 | 0.000 | 0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.041 | 0.025 | 0.019 | 0.012 | 0.011 | 0.044 | 0.027 | 0.020 | 0.013 | 0.012
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.113 | 0.061 | 0.041 | 0.032 | 0.022 | 0.117 | 0.063 | 0.042 | 0.033 | 0.023
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.000 | 0.000 | -0.001 | 0.001 | 0.002 | 0.002 | 0.002 | 0.001 | 0.000 | 0.001
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.081 | 0.049 | 0.032 | 0.027 | 0.019 | 0.099 | 0.068 | 0.054 | 0.044 | 0.036
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.193 | 0.120 | 0.087 | 0.064 | 0.049 | 0.203 | 0.137 | 0.107 | 0.084 | 0.072
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.010 | -0.007 | 0.001 | 0.001 | -0.001 | -0.003 | -0.002 | 0.003 | 0.000 | -0.001
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.128 | 0.091 | 0.070 | 0.050 | 0.041 | 0.152 | 0.113 | 0.089 | 0.075 | 0.065
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.275 | 0.191 | 0.146 | 0.117 | 0.101 | 0.292 | 0.218 | 0.171 | 0.146 | 0.125
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.000 | -0.003 | 0.002 | 0.012 | 0.002 | 0.000 | -0.006 | 0.008 | 0.004 | 0.000
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.228 | 0.161 | 0.131 | 0.104 | 0.078 | 0.247 | 0.190 | 0.157 | 0.127 | 0.109
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.436 | 0.311 | 0.252 | 0.199 | 0.172 | 0.464 | 0.339 | 0.282 | 0.234 | 0.202
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.001 | 0.000 | 0.000 | 0.001 | 0.001 | -0.001 | 0.000 | 0.000 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.046 | 0.027 | 0.018 | 0.014 | 0.011 | 0.050 | 0.029 | 0.020 | 0.015 | 0.012
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.122 | 0.065 | 0.043 | 0.033 | 0.026 | 0.125 | 0.067 | 0.045 | 0.034 | 0.027
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | 0.002 | -0.001 | 0.001 | -0.001 | -0.001 | 0.002 | -0.001 | 0.000 | 0.002
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.079 | 0.055 | 0.041 | 0.029 | 0.019 | 0.097 | 0.071 | 0.058 | 0.045 | 0.036
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.202 | 0.128 | 0.090 | 0.069 | 0.053 | 0.215 | 0.144 | 0.111 | 0.093 | 0.076
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.001 | 0.001 | 0.003 | -0.002 | 0.001 | 0.000 | -0.002 | 0.003 | 0.000 | -0.003
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.133 | 0.093 | 0.067 | 0.059 | 0.043 | 0.158 | 0.118 | 0.091 | 0.083 | 0.068
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.287 | 0.198 | 0.152 | 0.117 | 0.099 | 0.306 | 0.223 | 0.177 | 0.146 | 0.130
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.006 | -0.007 | 0.007 | -0.003 | 0.006 | -0.006 | -0.005 | -0.002 | -0.005 | 0.001
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.226 | 0.164 | 0.133 | 0.109 | 0.087 | 0.248 | 0.189 | 0.154 | 0.132 | 0.113
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.450 | 0.326 | 0.261 | 0.210 | 0.173 | 0.468 | 0.350 | 0.283 | 0.242 | 0.205
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.000 | 0.001 | 0.000 | 0.000 | 0.001 | 0.000 | 0.001 | 0.000 | 0.000
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.051 | 0.031 | 0.021 | 0.015 | 0.013 | 0.054 | 0.033 | 0.022 | 0.017 | 0.014
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.143 | 0.076 | 0.052 | 0.038 | 0.030 | 0.147 | 0.079 | 0.053 | 0.039 | 0.031
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | -0.004 | 0.002 | 0.002 | 0.001 | 0.000 | -0.004 | 0.002 | 0.002 | -0.001
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.093 | 0.058 | 0.046 | 0.031 | 0.025 | 0.111 | 0.080 | 0.065 | 0.052 | 0.043
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.217 | 0.141 | 0.104 | 0.080 | 0.061 | 0.228 | 0.158 | 0.126 | 0.104 | 0.086
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.002 | 0.002 | 0.008 | 0.001 | 0.006 | 0.000 | -0.001 | 0.003 | 0.003 | 0.004
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.139 | 0.112 | 0.079 | 0.065 | 0.049 | 0.164 | 0.133 | 0.104 | 0.091 | 0.071
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.297 | 0.209 | 0.161 | 0.130 | 0.115 | 0.319 | 0.235 | 0.192 | 0.161 | 0.139
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.003 | -0.007 | -0.001 | 0.000 | 0.000 | 0.000 | -0.002 | 0.002 | 0.008 | 0.004
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.247 | 0.173 | 0.133 | 0.121 | 0.093 | 0.269 | 0.198 | 0.166 | 0.143 | 0.120
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.477 | 0.346 | 0.265 | 0.223 | 0.183 | 0.493 | 0.371 | 0.299 | 0.250 | 0.219
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | -0.002 | 0.000 | 0.001 | 0.000 | -0.001 | -0.002 | 0.000 | 0.001 | -0.001
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.066 | 0.037 | 0.027 | 0.020 | 0.016 | 0.069 | 0.040 | 0.029 | 0.021 | 0.017
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.190 | 0.100 | 0.065 | 0.047 | 0.036 | 0.195 | 0.103 | 0.068 | 0.049 | 0.038
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | 0.002 | 0.001 | 0.001 | -0.004 | 0.003 | 0.000 | 0.001 | -0.002 | -0.003
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.116 | 0.077 | 0.053 | 0.042 | 0.030 | 0.136 | 0.099 | 0.074 | 0.064 | 0.052
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.259 | 0.173 | 0.128 | 0.099 | 0.080 | 0.273 | 0.191 | 0.151 | 0.126 | 0.107
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.001 | -0.006 | -0.002 | 0.005 | 0.002 | 0.001 | -0.004 | 0.000 | 0.004 | 0.001
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.171 | 0.113 | 0.091 | 0.076 | 0.060 | 0.196 | 0.145 | 0.122 | 0.104 | 0.086
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.344 | 0.248 | 0.189 | 0.154 | 0.127 | 0.362 | 0.272 | 0.219 | 0.185 | 0.162
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.008 | 0.012 | 0.001 | 0.003 | 0.010 | -0.006 | 0.007 | 0.002 | -0.001 | 0.004
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.281 | 0.197 | 0.168 | 0.134 | 0.118 | 0.303 | 0.227 | 0.188 | 0.159 | 0.140
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.507 | 0.374 | 0.305 | 0.253 | 0.222 | 0.526 | 0.396 | 0.332 | 0.283 | 0.248
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.001 | 0.001 | -0.001 | 0.000 | 0.000 | -0.001 | 0.001 | -0.001 | 0.001
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.079 | 0.046 | 0.031 | 0.025 | 0.019 | 0.084 | 0.049 | 0.033 | 0.027 | 0.021
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.217 | 0.123 | 0.080 | 0.057 | 0.043 | 0.223 | 0.126 | 0.083 | 0.059 | 0.045
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | 0.000 | 0.002 | -0.003 | -0.001 | 0.001 | 0.001 | 0.000 | -0.001 | -0.001
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.141 | 0.091 | 0.064 | 0.049 | 0.040 | 0.159 | 0.116 | 0.090 | 0.073 | 0.063
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.298 | 0.201 | 0.150 | 0.118 | 0.093 | 0.311 | 0.222 | 0.176 | 0.146 | 0.122
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.002 | 0.005 | -0.003 | -0.001 | -0.003 | -0.001 | 0.003 | -0.002 | 0.003 | 0.001
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.198 | 0.135 | 0.109 | 0.082 | 0.067 | 0.222 | 0.168 | 0.142 | 0.116 | 0.098
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.387 | 0.280 | 0.220 | 0.179 | 0.151 | 0.408 | 0.308 | 0.251 | 0.213 | 0.184
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.013 | -0.007 | -0.001 | 0.001 | 0.000 | 0.004 | -0.001 | 0.001 | -0.003 | 0.000
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.288 | 0.221 | 0.175 | 0.138 | 0.121 | 0.325 | 0.249 | 0.202 | 0.173 | 0.148
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.553 | 0.405 | 0.325 | 0.271 | 0.238 | 0.571 | 0.435 | 0.358 | 0.301 | 0.270

Table E2 Absolute bias in the estimated intercept, with R studies imputed (from 1-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.004 | -0.001 | -0.001 | -0.001 | 0.000 | -0.005 | -0.001 | -0.002 | -0.002 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.012 | 0.003 | 0.002 | -0.001 | 0.001 | 0.012 | 0.003 | 0.002 | -0.001 | 0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.058 | 0.020 | 0.009 | 0.006 | 0.001 | 0.058 | 0.020 | 0.010 | 0.006 | 0.001
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.008 | -0.005 | -0.004 | -0.002 | -0.001 | -0.014 | -0.009 | -0.007 | -0.007 | -0.005
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.034 | 0.010 | 0.000 | -0.001 | -0.006 | 0.030 | 0.005 | -0.003 | -0.008 | -0.010
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.138 | 0.063 | 0.033 | 0.014 | 0.004 | 0.136 | 0.061 | 0.029 | 0.008 | -0.002
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.027 | -0.023 | -0.009 | -0.008 | -0.008 | -0.039 | -0.033 | -0.021 | -0.020 | -0.017
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.067 | 0.032 | 0.012 | -0.003 | -0.004 | 0.051 | 0.013 | -0.007 | -0.019 | -0.017
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.211 | 0.123 | 0.074 | 0.046 | 0.035 | 0.202 | 0.111 | 0.058 | 0.030 | 0.015
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.042 | -0.040 | -0.028 | -0.017 | -0.019 | -0.078 | -0.074 | -0.050 | -0.048 | -0.042
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.127 | 0.069 | 0.037 | 0.019 | -0.005 | 0.092 | 0.035 | 0.003 | -0.019 | -0.030
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.352 | 0.208 | 0.142 | 0.090 | 0.062 | 0.331 | 0.176 | 0.109 | 0.059 | 0.026
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.003 | -0.002 | -0.001 | 0.000 | -0.004 | -0.004 | -0.002 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.015 | 0.004 | 0.002 | 0.000 | 0.000 | 0.016 | 0.004 | 0.002 | 0.001 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.064 | 0.023 | 0.010 | 0.007 | 0.004 | 0.064 | 0.023 | 0.011 | 0.007 | 0.005
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.009 | -0.004 | -0.005 | -0.001 | -0.003 | -0.017 | -0.010 | -0.011 | -0.007 | -0.004
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.029 | 0.014 | 0.007 | 0.000 | -0.005 | 0.026 | 0.005 | -0.001 | -0.008 | -0.011
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.144 | 0.073 | 0.035 | 0.019 | 0.006 | 0.144 | 0.068 | 0.030 | 0.015 | 0.000
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.018 | -0.013 | -0.008 | -0.010 | -0.006 | -0.038 | -0.030 | -0.022 | -0.020 | -0.020
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.070 | 0.030 | 0.008 | 0.006 | -0.005 | 0.057 | 0.012 | -0.008 | -0.009 | -0.016
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.221 | 0.126 | 0.076 | 0.045 | 0.029 | 0.212 | 0.112 | 0.059 | 0.030 | 0.013
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.053 | -0.040 | -0.025 | -0.033 | -0.016 | -0.093 | -0.070 | -0.061 | -0.060 | -0.044
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.134 | 0.066 | 0.043 | 0.019 | 0.005 | 0.097 | 0.030 | -0.001 | -0.013 | -0.024
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.361 | 0.220 | 0.155 | 0.093 | 0.062 | 0.330 | 0.187 | 0.111 | 0.062 | 0.026
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.002 | -0.001 | -0.001 | -0.001 | -0.004 | -0.003 | -0.001 | -0.001 | -0.002
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.018 | 0.006 | 0.003 | 0.001 | 0.002 | 0.016 | 0.006 | 0.002 | 0.001 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.077 | 0.028 | 0.015 | 0.009 | 0.005 | 0.077 | 0.028 | 0.015 | 0.008 | 0.005
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.008 | -0.010 | -0.002 | -0.001 | -0.002 | -0.018 | -0.017 | -0.008 | -0.006 | -0.007
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.041 | 0.015 | 0.009 | -0.001 | -0.002 | 0.035 | 0.010 | 0.002 | -0.008 | -0.009
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.156 | 0.080 | 0.046 | 0.029 | 0.015 | 0.152 | 0.074 | 0.039 | 0.022 | 0.006
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.020 | -0.013 | -0.003 | -0.009 | -0.002 | -0.040 | -0.032 | -0.023 | -0.019 | -0.015
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.070 | 0.044 | 0.019 | 0.010 | -0.001 | 0.054 | 0.021 | 0.000 | -0.007 | -0.018
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.225 | 0.127 | 0.083 | 0.057 | 0.044 | 0.217 | 0.110 | 0.068 | 0.037 | 0.023
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.043 | -0.043 | -0.033 | -0.028 | -0.022 | -0.084 | -0.071 | -0.058 | -0.046 | -0.041
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.149 | 0.069 | 0.035 | 0.029 | 0.005 | 0.111 | 0.028 | 0.002 | -0.012 | -0.031
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.385 | 0.238 | 0.148 | 0.103 | 0.068 | 0.349 | 0.202 | 0.113 | 0.060 | 0.034
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.004 | -0.005 | -0.002 | -0.001 | -0.002 | -0.006 | -0.006 | -0.003 | -0.001 | -0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.028 | 0.010 | 0.006 | 0.002 | 0.002 | 0.025 | 0.008 | 0.004 | 0.001 | 0.000
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.110 | 0.045 | 0.023 | 0.012 | 0.007 | 0.109 | 0.044 | 0.021 | 0.010 | 0.005
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.008 | -0.005 | -0.004 | -0.002 | -0.007 | -0.017 | -0.015 | -0.010 | -0.011 | -0.011
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.062 | 0.029 | 0.013 | 0.006 | 0.000 | 0.053 | 0.019 | 0.000 | -0.002 | -0.008
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.183 | 0.099 | 0.062 | 0.039 | 0.025 | 0.177 | 0.088 | 0.051 | 0.030 | 0.014
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.019 | -0.020 | -0.014 | -0.004 | -0.006 | -0.040 | -0.038 | -0.030 | -0.019 | -0.020
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.104 | 0.047 | 0.028 | 0.015 | 0.009 | 0.084 | 0.029 | 0.006 | -0.007 | -0.013
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.263 | 0.161 | 0.102 | 0.070 | 0.046 | 0.244 | 0.138 | 0.079 | 0.046 | 0.026
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.049 | -0.022 | -0.029 | -0.024 | -0.014 | -0.088 | -0.063 | -0.060 | -0.055 | -0.042
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.176 | 0.092 | 0.069 | 0.034 | 0.029 | 0.128 | 0.055 | 0.017 | -0.008 | -0.017
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.405 | 0.253 | 0.181 | 0.123 | 0.098 | 0.367 | 0.207 | 0.138 | 0.081 | 0.053
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.005 | -0.004 | -0.001 | -0.003 | -0.001 | -0.008 | -0.006 | -0.002 | -0.004 | -0.002
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.038 | 0.013 | 0.006 | 0.004 | 0.002 | 0.034 | 0.007 | 0.001 | 0.001 | -0.001
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.136 | 0.063 | 0.032 | 0.016 | 0.007 | 0.134 | 0.060 | 0.028 | 0.011 | 0.002
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.009 | -0.007 | -0.002 | -0.007 | -0.005 | -0.023 | -0.017 | -0.014 | -0.013 | -0.011
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.081 | 0.039 | 0.018 | 0.009 | 0.006 | 0.066 | 0.026 | 0.006 | -0.002 | -0.007
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.214 | 0.122 | 0.075 | 0.052 | 0.033 | 0.204 | 0.109 | 0.062 | 0.039 | 0.019
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.018 | -0.010 | -0.015 | -0.012 | -0.012 | -0.046 | -0.033 | -0.034 | -0.024 | -0.023
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.119 | 0.056 | 0.040 | 0.018 | 0.011 | 0.093 | 0.033 | 0.016 | -0.005 | -0.011
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.294 | 0.187 | 0.123 | 0.087 | 0.061 | 0.275 | 0.163 | 0.095 | 0.062 | 0.032
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.032 | -0.046 | -0.031 | -0.025 | -0.022 | -0.087 | -0.081 | -0.067 | -0.060 | -0.052
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.176 | 0.110 | 0.070 | 0.039 | 0.027 | 0.136 | 0.063 | 0.021 | -0.005 | -0.020
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.444 | 0.276 | 0.187 | 0.136 | 0.106 | 0.397 | 0.232 | 0.142 | 0.087 | 0.060

Table E3 Absolute bias in the estimated intercept, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.007 | -0.004 | -0.004 | -0.004 | -0.003 | -0.009 | -0.006 | -0.005 | -0.005 | -0.004
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.017 | 0.006 | 0.004 | 0.000 | 0.001 | 0.019 | 0.007 | 0.004 | 0.000 | 0.002
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.070 | 0.030 | 0.016 | 0.011 | 0.005 | 0.072 | 0.031 | 0.018 | 0.012 | 0.005
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.019 | -0.018 | -0.015 | -0.013 | -0.011 | -0.034 | -0.031 | -0.029 | -0.029 | -0.027
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.046 | 0.019 | 0.005 | 0.000 | -0.007 | 0.045 | 0.017 | 0.004 | -0.005 | -0.012
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.153 | 0.081 | 0.050 | 0.029 | 0.017 | 0.154 | 0.083 | 0.050 | 0.027 | 0.016
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.045 | -0.042 | -0.031 | -0.031 | -0.032 | -0.069 | -0.069 | -0.060 | -0.062 | -0.059
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.081 | 0.046 | 0.023 | 0.004 | -0.001 | 0.071 | 0.032 | 0.007 | -0.008 | -0.013
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.232 | 0.146 | 0.100 | 0.072 | 0.057 | 0.226 | 0.142 | 0.093 | 0.065 | 0.045
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.071 | -0.077 | -0.067 | -0.060 | -0.067 | -0.127 | -0.134 | -0.114 | -0.120 | -0.119
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.155 | 0.096 | 0.063 | 0.035 | 0.005 | 0.126 | 0.069 | 0.035 | 0.002 | -0.017
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.383 | 0.249 | 0.187 | 0.134 | 0.105 | 0.369 | 0.230 | 0.166 | 0.115 | 0.080
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.006 | -0.006 | -0.005 | -0.004 | -0.003 | -0.008 | -0.008 | -0.006 | -0.005 | -0.004
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.021 | 0.008 | 0.004 | 0.001 | 0.001 | 0.022 | 0.009 | 0.005 | 0.002 | 0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.077 | 0.033 | 0.018 | 0.012 | 0.008 | 0.077 | 0.034 | 0.020 | 0.013 | 0.009
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.020 | -0.016 | -0.017 | -0.014 | -0.014 | -0.037 | -0.031 | -0.033 | -0.030 | -0.026
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.041 | 0.022 | 0.011 | 0.001 | -0.005 | 0.040 | 0.017 | 0.007 | -0.006 | -0.011
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.160 | 0.091 | 0.052 | 0.034 | 0.020 | 0.161 | 0.090 | 0.053 | 0.035 | 0.018
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.037 | -0.034 | -0.030 | -0.033 | -0.031 | -0.069 | -0.065 | -0.061 | -0.061 | -0.064
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.087 | 0.046 | 0.020 | 0.013 | -0.001 | 0.079 | 0.033 | 0.008 | 0.001 | -0.012
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.240 | 0.153 | 0.104 | 0.071 | 0.052 | 0.236 | 0.147 | 0.095 | 0.064 | 0.044
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.082 | -0.077 | -0.068 | -0.077 | -0.061 | -0.141 | -0.130 | -0.133 | -0.133 | -0.120
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.157 | 0.090 | 0.061 | 0.037 | 0.017 | 0.127 | 0.061 | 0.025 | 0.009 | -0.009
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.390 | 0.264 | 0.198 | 0.140 | 0.103 | 0.369 | 0.241 | 0.168 | 0.120 | 0.079
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.007 | -0.006 | -0.004 | -0.004 | -0.004 | -0.010 | -0.008 | -0.006 | -0.005 | -0.006
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.024 | 0.011 | 0.005 | 0.002 | 0.002 | 0.023 | 0.011 | 0.005 | 0.002 | 0.002
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.090 | 0.040 | 0.024 | 0.015 | 0.010 | 0.091 | 0.040 | 0.025 | 0.016 | 0.010
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.018 | -0.021 | -0.014 | -0.012 | -0.013 | -0.035 | -0.039 | -0.031 | -0.030 | -0.031
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.053 | 0.023 | 0.014 | 0.001 | -0.003 | 0.050 | 0.022 | 0.009 | -0.004 | -0.009
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.173 | 0.099 | 0.064 | 0.044 | 0.027 | 0.171 | 0.097 | 0.062 | 0.042 | 0.024
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.039 | -0.034 | -0.025 | -0.034 | -0.028 | -0.073 | -0.070 | -0.065 | -0.065 | -0.060
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.088 | 0.060 | 0.031 | 0.017 | 0.003 | 0.077 | 0.042 | 0.016 | 0.003 | -0.013
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.248 | 0.156 | 0.112 | 0.083 | 0.067 | 0.245 | 0.145 | 0.105 | 0.072 | 0.053
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.069 | -0.079 | -0.076 | -0.075 | -0.069 | -0.132 | -0.136 | -0.128 | -0.124 | -0.122
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.175 | 0.097 | 0.055 | 0.048 | 0.018 | 0.143 | 0.063 | 0.030 | 0.011 | -0.014
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.415 | 0.284 | 0.194 | 0.152 | 0.111 | 0.389 | 0.259 | 0.173 | 0.121 | 0.090
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.008 | -0.009 | -0.006 | -0.005 | -0.005 | -0.012 | -0.012 | -0.010 | -0.008 | -0.008
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.035 | 0.015 | 0.009 | 0.004 | 0.003 | 0.034 | 0.013 | 0.007 | 0.003 | 0.001
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.124 | 0.058 | 0.033 | 0.020 | 0.013 | 0.124 | 0.058 | 0.033 | 0.020 | 0.012
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.019 | -0.016 | -0.016 | -0.016 | -0.020 | -0.038 | -0.039 | -0.037 | -0.041 | -0.040
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.072 | 0.038 | 0.018 | 0.008 | 0.000 | 0.067 | 0.033 | 0.009 | 0.001 | -0.008
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.201 | 0.122 | 0.082 | 0.057 | 0.040 | 0.198 | 0.115 | 0.078 | 0.054 | 0.035
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.037 | -0.042 | -0.039 | -0.031 | -0.033 | -0.074 | -0.078 | -0.076 | -0.068 | -0.071
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.121 | 0.063 | 0.041 | 0.024 | 0.014 | 0.107 | 0.050 | 0.025 | 0.005 | -0.006
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.286 | 0.191 | 0.133 | 0.099 | 0.073 | 0.273 | 0.176 | 0.118 | 0.085 | 0.061
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.084 | -0.059 | -0.071 | -0.069 | -0.063 | -0.143 | -0.126 | -0.133 | -0.130 | -0.124
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.209 | 0.121 | 0.092 | 0.053 | 0.041 | 0.168 | 0.091 | 0.048 | 0.018 | 0.000
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.438 | 0.298 | 0.233 | 0.173 | 0.143 | 0.410 | 0.264 | 0.201 | 0.142 | 0.109
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.010 | -0.009 | -0.007 | -0.008 | -0.006 | -0.017 | -0.015 | -0.012 | -0.013 | -0.012
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.046 | 0.019 | 0.009 | 0.006 | 0.002 | 0.043 | 0.015 | 0.005 | 0.002 | -0.002
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.150 | 0.076 | 0.044 | 0.026 | 0.015 | 0.149 | 0.074 | 0.041 | 0.023 | 0.012
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.022 | -0.020 | -0.017 | -0.023 | -0.020 | -0.047 | -0.045 | -0.044 | -0.045 | -0.044
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.094 | 0.049 | 0.026 | 0.013 | 0.006 | 0.082 | 0.039 | 0.016 | 0.003 | -0.006
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.233 | 0.145 | 0.098 | 0.071 | 0.049 | 0.225 | 0.137 | 0.091 | 0.064 | 0.041
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.038 | -0.032 | -0.039 | -0.038 | -0.041 | -0.083 | -0.076 | -0.081 | -0.074 | -0.078
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.139 | 0.074 | 0.054 | 0.027 | 0.016 | 0.117 | 0.056 | 0.036 | 0.008 | -0.003
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.320 | 0.220 | 0.155 | 0.118 | 0.090 | 0.305 | 0.204 | 0.137 | 0.102 | 0.070
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.059 | -0.086 | -0.075 | -0.076 | -0.073 | -0.141 | -0.150 | -0.140 | -0.142 | -0.137
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.206 | 0.139 | 0.094 | 0.060 | 0.040 | 0.174 | 0.098 | 0.052 | 0.022 | -0.003
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.482 | 0.328 | 0.243 | 0.187 | 0.157 | 0.442 | 0.294 | 0.210 | 0.150 | 0.124

Table E4 Coverage probability of the estimated intercept, with no correction for publication bias (from 1-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 94.9% | 94.9% | 95.4% | 95.3% | 96.2% | 96.2% | 95.9% | 96.4% | 96.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 94.7% | 94.4% | 94.8% | 94.8% | 94.5% | 94.9% | 94.9% | 95.2% | 95.1% | 94.7%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.7% | 90.2% | 91.3% | 91.9% | 92.8% | 87.9% | 90.4% | 91.6% | 91.9% | 93.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.4% | 60.0% | 56.3% | 55.5% | 54.0% | 92.2% | 92.4% | 93.2% | 93.1% | 94.2%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.8% | 61.8% | 57.4% | 55.6% | 53.6% | 82.5% | 85.9% | 88.9% | 89.8% | 90.4%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 58.1% | 56.2% | 54.6% | 54.1% | 53.0% | 65.3% | 70.3% | 74.4% | 79.7% | 82.5%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 46.0% | 41.4% | 38.9% | 37.7% | 36.6% | 93.1% | 92.9% | 93.4% | 93.7% | 93.6%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 48.8% | 43.5% | 40.2% | 37.9% | 37.1% | 82.3% | 86.6% | 88.2% | 89.2% | 89.9%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 41.1% | 39.9% | 38.8% | 36.6% | 34.9% | 59.5% | 66.6% | 72.7% | 75.7% | 78.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.9% | 26.0% | 23.7% | 22.0% | 21.3% | 92.6% | 93.1% | 93.1% | 93.9% | 93.7%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 31.3% | 27.8% | 24.9% | 23.5% | 24.0% | 81.1% | 84.0% | 85.9% | 87.1% | 89.1%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.3% | 25.0% | 24.2% | 23.7% | 21.7% | 55.7% | 65.3% | 69.1% | 72.5% | 75.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 94.9% | 94.8% | 94.6% | 94.8% | 96.1% | 96.0% | 95.8% | 95.8% | 96.0%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.6% | 94.2% | 95.0% | 94.5% | 94.6% | 93.9% | 94.4% | 95.3% | 94.8% | 95.1%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 86.2% | 89.1% | 90.8% | 91.9% | 91.9% | 86.4% | 89.2% | 90.9% | 92.0% | 92.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.3% | 58.3% | 57.4% | 56.0% | 53.6% | 92.4% | 92.9% | 93.4% | 93.6% | 93.5%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 64.3% | 59.7% | 57.6% | 54.7% | 53.1% | 82.6% | 85.9% | 87.9% | 89.4% | 90.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 56.2% | 55.0% | 53.6% | 53.0% | 53.1% | 63.5% | 68.8% | 73.5% | 77.8% | 81.9%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.5% | 41.2% | 38.9% | 37.9% | 35.5% | 92.7% | 93.3% | 94.1% | 93.9% | 94.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 48.7% | 41.7% | 38.9% | 37.2% | 37.8% | 81.5% | 84.9% | 87.8% | 86.8% | 90.1%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 38.9% | 37.7% | 38.3% | 36.6% | 35.8% | 57.0% | 65.5% | 71.9% | 75.1% | 77.0%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.9% | 25.9% | 24.2% | 23.0% | 20.9% | 93.2% | 93.2% | 93.8% | 93.2% | 93.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.7% | 29.7% | 26.0% | 24.6% | 23.7% | 80.4% | 84.8% | 86.6% | 86.9% | 88.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.3% | 24.4% | 24.5% | 22.7% | 22.5% | 56.2% | 63.5% | 68.9% | 71.6% | 75.1%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.4% | 95.4% | 94.5% | 94.9% | 94.6% | 95.6% | 96.4% | 95.8% | 96.2% | 95.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.6% | 93.3% | 94.0% | 94.3% | 94.4% | 93.0% | 93.6% | 94.4% | 94.6% | 94.6%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 82.9% | 86.9% | 89.3% | 90.4% | 91.6% | 83.2% | 87.0% | 89.4% | 90.5% | 91.6%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.7% | 61.2% | 56.3% | 54.8% | 53.2% | 91.6% | 93.5% | 93.8% | 93.8% | 93.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 64.5% | 59.6% | 57.3% | 55.3% | 54.6% | 81.1% | 84.1% | 86.2% | 89.0% | 89.7%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 53.5% | 53.2% | 51.9% | 52.0% | 51.1% | 61.5% | 65.3% | 70.4% | 75.2% | 78.7%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.1% | 41.3% | 39.1% | 36.8% | 34.4% | 93.3% | 93.1% | 93.6% | 93.6% | 92.8%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 46.8% | 42.1% | 41.0% | 37.5% | 35.8% | 80.6% | 84.2% | 86.9% | 87.7% | 89.1%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 38.9% | 37.7% | 35.8% | 36.0% | 34.8% | 56.3% | 64.2% | 68.1% | 72.3% | 73.6%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.1% | 26.5% | 24.8% | 22.4% | 21.7% | 92.3% | 92.7% | 92.7% | 93.3% | 93.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 31.8% | 28.3% | 26.0% | 22.9% | 22.5% | 80.2% | 83.4% | 85.6% | 86.2% | 87.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 24.4% | 23.3% | 23.3% | 22.4% | 22.8% | 53.6% | 61.0% | 66.1% | 71.2% | 72.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.9% | 95.2% | 95.3% | 95.0% | 94.8% | 95.9% | 96.2% | 96.4% | 96.1% | 95.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 90.5% | 93.4% | 93.1% | 93.8% | 93.6% | 91.0% | 93.6% | 93.5% | 94.1% | 94.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 74.8% | 81.0% | 84.6% | 87.4% | 89.4% | 75.2% | 81.0% | 84.6% | 87.4% | 89.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.9% | 59.8% | 58.4% | 55.2% | 53.7% | 92.2% | 92.6% | 93.8% | 93.4% | 94.0%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 61.4% | 57.7% | 56.6% | 53.8% | 54.1% | 77.7% | 81.9% | 86.1% | 86.4% | 88.5%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 46.2% | 46.4% | 48.3% | 46.6% | 48.5% | 53.5% | 59.3% | 64.2% | 67.9% | 72.7%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.3% | 41.9% | 38.2% | 36.7% | 34.8% | 92.7% | 92.8% | 93.1% | 93.8% | 93.0%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.1% | 41.7% | 38.4% | 37.4% | 36.4% | 77.9% | 81.7% | 84.1% | 86.3% | 87.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 33.6% | 32.5% | 34.4% | 32.5% | 33.0% | 50.5% | 56.5% | 62.5% | 67.4% | 69.5%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.3% | 26.7% | 24.0% | 22.4% | 21.1% | 91.8% | 93.4% | 93.2% | 94.0% | 93.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.0% | 27.9% | 26.1% | 23.5% | 23.6% | 78.0% | 81.4% | 83.4% | 85.2% | 86.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 22.3% | 22.0% | 20.3% | 21.6% | 21.4% | 51.0% | 56.7% | 61.2% | 65.0% | 68.2%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.1% | 95.1% | 95.2% | 95.6% | 95.3% | 96.1% | 95.9% | 96.0% | 96.4% | 96.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 89.1% | 91.9% | 92.5% | 92.8% | 93.3% | 89.6% | 92.2% | 92.7% | 93.1% | 93.6%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 71.6% | 75.5% | 79.6% | 84.4% | 87.1% | 71.9% | 75.6% | 79.5% | 84.4% | 87.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.4% | 59.4% | 57.2% | 54.7% | 54.4% | 92.1% | 92.0% | 93.5% | 93.0% | 94.1%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 57.8% | 55.9% | 54.4% | 52.7% | 52.5% | 74.0% | 78.5% | 82.5% | 85.2% | 86.7%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 40.0% | 40.7% | 43.1% | 43.0% | 45.3% | 47.8% | 52.5% | 57.9% | 61.3% | 66.5%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.7% | 40.7% | 39.3% | 37.0% | 35.1% | 92.8% | 93.4% | 93.9% | 93.2% | 94.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.1% | 40.5% | 39.0% | 37.0% | 35.7% | 75.2% | 79.1% | 81.0% | 84.7% | 85.5%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 28.3% | 30.0% | 30.2% | 30.0% | 31.0% | 44.6% | 51.0% | 56.5% | 60.3% | 65.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.7% | 26.5% | 23.5% | 22.8% | 21.8% | 92.5% | 93.4% | 93.7% | 93.0% | 94.3%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.6% | 27.2% | 25.1% | 24.5% | 22.8% | 75.3% | 79.6% | 81.8% | 83.3% | 85.1%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 20.0% | 20.8% | 20.7% | 20.4% | 19.9% | 47.1% | 53.5% | 57.9% | 62.6% | 63.6%

Table E5 Coverage probability of the estimated intercept, with R studies imputed (from 1-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.6% | 94.6% | 94.5% | 95.2% | 95.1% | 95.8% | 96.1% | 95.8% | 96.3% | 96.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.1% | 92.6% | 93.6% | 93.7% | 93.3% | 94.3% | 93.9% | 94.7% | 94.7% | 94.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 90.6% | 91.3% | 91.9% | 91.7% | 91.9% | 91.4% | 92.5% | 93.0% | 92.6% | 92.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.3% | 59.5% | 56.2% | 55.1% | 53.7% | 90.7% | 91.4% | 92.0% | 92.4% | 93.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 60.9% | 58.0% | 53.6% | 51.7% | 50.7% | 81.4% | 82.8% | 84.5% | 85.5% | 86.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 61.0% | 57.0% | 53.5% | 51.4% | 49.0% | 71.6% | 76.2% | 78.1% | 80.0% | 81.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.5% | 40.3% | 38.1% | 37.1% | 36.2% | 89.4% | 89.1% | 90.5% | 90.9% | 91.4%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.5% | 40.0% | 36.2% | 35.3% | 33.9% | 80.5% | 82.3% | 82.2% | 82.0% | 82.6%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 44.0% | 40.3% | 37.7% | 33.9% | 31.1% | 66.4% | 73.9% | 77.5% | 77.9% | 78.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.4% | 24.8% | 23.1% | 21.6% | 20.7% | 87.1% | 87.4% | 88.2% | 89.1% | 89.9%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.8% | 24.2% | 22.3% | 21.7% | 20.8% | 78.6% | 79.4% | 80.0% | 79.9% | 80.3%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 27.4% | 25.3% | 23.2% | 22.2% | 20.9% | 64.8% | 72.6% | 74.7% | 75.1% | 75.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.6% | 94.6% | 94.6% | 94.2% | 94.6% | 95.9% | 95.9% | 95.8% | 95.6% | 95.9%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.1% | 92.4% | 93.5% | 93.0% | 93.9% | 93.1% | 93.3% | 94.4% | 94.1% | 94.9%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 90.2% | 91.1% | 90.9% | 92.1% | 92.4% | 90.9% | 92.2% | 92.0% | 93.2% | 93.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.1% | 57.7% | 56.9% | 55.8% | 53.4% | 90.6% | 91.9% | 92.3% | 92.7% | 92.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 61.3% | 56.9% | 54.1% | 51.7% | 51.1% | 81.9% | 83.0% | 84.4% | 84.9% | 86.9%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 60.6% | 57.2% | 53.1% | 51.2% | 50.3% | 71.6% | 76.0% | 78.0% | 80.2% | 81.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.5% | 40.1% | 38.2% | 37.4% | 35.2% | 89.1% | 90.0% | 90.9% | 91.4% | 91.7%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.9% | 38.8% | 35.6% | 32.9% | 34.0% | 80.1% | 80.6% | 81.7% | 81.2% | 83.7%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 42.0% | 38.6% | 37.8% | 35.5% | 32.5% | 65.2% | 73.4% | 77.9% | 77.9% | 77.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.1% | 25.2% | 23.3% | 21.9% | 20.4% | 86.6% | 88.0% | 88.1% | 88.1% | 89.5%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.9% | 26.8% | 22.9% | 21.4% | 20.5% | 78.8% | 80.2% | 79.9% | 80.5% | 81.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 28.8% | 24.4% | 23.3% | 21.0% | 21.0% | 64.1% | 71.1% | 74.7% | 74.5% | 75.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.1% | 94.8% | 94.4% | 94.7% | 94.5% | 95.5% | 96.2% | 95.8% | 96.1% | 95.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.7% | 92.2% | 92.9% | 93.2% | 93.7% | 92.7% | 93.4% | 94.1% | 94.6% | 94.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 88.6% | 90.3% | 91.3% | 91.4% | 92.2% | 89.3% | 91.2% | 92.3% | 92.2% | 93.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.5% | 60.6% | 55.8% | 54.5% | 52.9% | 90.0% | 91.7% | 92.5% | 92.9% | 92.7%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.5% | 56.0% | 54.5% | 52.1% | 52.0% | 81.6% | 81.7% | 83.8% | 84.7% | 85.2%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 59.5% | 56.5% | 51.9% | 51.6% | 48.8% | 69.9% | 74.5% | 77.1% | 79.6% | 80.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 42.9% | 40.7% | 38.3% | 36.7% | 33.5% | 89.6% | 89.9% | 90.4% | 91.4% | 90.7%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 44.2% | 37.8% | 37.8% | 34.7% | 32.5% | 79.4% | 80.9% | 81.8% | 80.9% | 81.8%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 42.0% | 40.5% | 36.7% | 34.9% | 32.2% | 65.0% | 73.8% | 75.1% | 77.2% | 76.5%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.0% | 25.0% | 23.7% | 21.8% | 21.3% | 86.0% | 87.1% | 87.4% | 88.6% | 89.1%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.5% | 25.4% | 23.2% | 20.9% | 20.4% | 78.7% | 78.7% | 79.9% | 79.3% | 79.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.5% | 24.8% | 21.8% | 20.8% | 20.0% | 62.9% | 70.6% | 73.9% | 76.3% | 75.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.4% | 94.5% | 94.9% | 94.8% | 94.7% | 95.6% | 95.8% | 96.2% | 96.0% | 95.7%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 89.3% | 91.2% | 91.9% | 92.2% | 92.8% | 91.1% | 92.5% | 93.3% | 93.2% | 93.9%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 83.8% | 87.8% | 88.4% | 89.0% | 90.1% | 84.9% | 88.6% | 89.8% | 90.4% | 91.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.7% | 58.6% | 57.6% | 54.9% | 53.5% | 90.4% | 90.9% | 92.3% | 92.2% | 92.7%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 60.3% | 55.2% | 54.3% | 50.8% | 50.7% | 79.5% | 81.5% | 83.4% | 83.5% | 84.2%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 55.1% | 54.8% | 52.6% | 49.0% | 47.0% | 66.1% | 73.4% | 76.5% | 76.7% | 78.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.1% | 40.9% | 37.3% | 36.3% | 34.2% | 88.5% | 89.3% | 89.6% | 90.8% | 90.5%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.4% | 38.1% | 35.8% | 34.4% | 33.3% | 79.1% | 79.1% | 80.0% | 81.0% | 80.7%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 39.3% | 36.9% | 35.8% | 33.4% | 31.6% | 63.1% | 71.1% | 74.6% | 75.9% | 76.4%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 25.8% | 25.4% | 23.3% | 21.5% | 20.6% | 86.6% | 87.7% | 88.5% | 89.3% | 89.1%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.0% | 25.6% | 23.2% | 21.7% | 20.5% | 78.3% | 78.9% | 78.9% | 78.7% | 80.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.4% | 24.4% | 22.0% | 21.2% | 20.8% | 61.0% | 69.3% | 73.0% | 73.9% | 74.8%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 94.6% | 94.7% | 95.3% | 95.0% | 95.4% | 95.5% | 95.9% | 96.2% | 96.3%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 88.2% | 89.1% | 89.8% | 90.9% | 92.0% | 89.7% | 90.6% | 90.7% | 91.7% | 92.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 80.2% | 83.4% | 84.2% | 86.1% | 85.6% | 81.7% | 84.4% | 85.3% | 87.2% | 86.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.2% | 58.6% | 56.9% | 54.0% | 54.0% | 90.0% | 90.4% | 91.8% | 91.8% | 92.8%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 59.9% | 54.4% | 52.0% | 50.3% | 49.2% | 78.3% | 79.6% | 80.7% | 82.7% | 83.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 50.0% | 51.0% | 49.8% | 48.3% | 46.3% | 62.8% | 70.6% | 74.1% | 76.1% | 76.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.1% | 40.0% | 38.3% | 36.3% | 34.2% | 88.5% | 90.0% | 90.2% | 90.0% | 90.7%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 42.9% | 37.8% | 35.9% | 33.4% | 32.3% | 77.5% | 79.3% | 80.1% | 79.6% | 80.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 36.4% | 36.0% | 33.7% | 33.9% | 31.2% | 59.1% | 67.7% | 74.0% | 74.4% | 75.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.5% | 25.0% | 22.4% | 22.3% | 21.0% | 86.9% | 87.4% | 87.9% | 87.8% | 89.0%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.2% | 25.5% | 23.2% | 21.7% | 20.0% | 76.6% | 78.5% | 78.3% | 78.4% | 78.1%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 23.8% | 23.2% | 22.7% | 20.5% | 19.9% | 60.2% | 67.9% | 71.2% | 71.8% | 72.2%

Table E6 Coverage probability of the estimated intercept, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.0% | 94.2% | 94.0% | 94.4% | 94.5% | 95.5% | 96.0% | 95.4% | 95.8% | 95.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.6% | 93.1% | 93.6% | 93.6% | 93.0% | 94.7% | 94.3% | 94.5% | 94.8% | 94.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 90.3% | 92.2% | 92.7% | 92.5% | 92.6% | 90.9% | 92.9% | 93.5% | 93.3% | 93.6%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 59.7% | 57.7% | 54.2% | 53.1% | 51.7% | 88.2% | 89.0% | 88.2% | 88.4% | 89.2%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.0% | 59.1% | 54.5% | 51.7% | 49.7% | 82.2% | 83.7% | 85.4% | 85.3% | 85.4%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 60.7% | 57.9% | 55.1% | 53.2% | 50.3% | 70.7% | 76.1% | 78.5% | 81.5% | 82.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.3% | 38.8% | 36.2% | 35.8% | 33.9% | 86.9% | 84.7% | 85.1% | 84.3% | 84.2%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 46.2% | 41.6% | 37.4% | 35.9% | 33.5% | 81.5% | 84.2% | 83.0% | 83.2% | 83.1%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 43.2% | 40.6% | 38.1% | 35.2% | 31.8% | 64.9% | 72.6% | 76.6% | 78.7% | 79.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 25.5% | 23.2% | 21.3% | 20.1% | 19.4% | 84.3% | 82.4% | 82.6% | 81.5% | 80.1%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.3% | 25.6% | 23.0% | 20.9% | 21.2% | 80.1% | 81.3% | 82.2% | 81.2% | 81.5%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 27.1% | 25.2% | 23.8% | 22.6% | 21.2% | 62.4% | 70.8% | 73.7% | 75.1% | 76.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 94.2% | 94.1% | 94.1% | 94.2% | 95.5% | 95.8% | 95.6% | 95.6% | 95.7%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.5% | 92.8% | 93.8% | 93.5% | 93.6% | 93.8% | 93.6% | 94.9% | 94.4% | 94.8%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 89.7% | 91.1% | 91.6% | 92.8% | 92.9% | 90.4% | 91.9% | 92.6% | 93.9% | 93.9%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 59.8% | 56.7% | 54.9% | 54.2% | 51.3% | 88.3% | 88.5% | 88.9% | 88.4% | 88.1%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.7% | 57.4% | 54.6% | 51.8% | 50.4% | 82.8% | 83.7% | 84.7% | 84.7% | 85.6%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 59.6% | 57.4% | 54.5% | 53.0% | 51.3% | 70.0% | 75.0% | 78.4% | 80.4% | 82.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 41.9% | 38.4% | 36.5% | 35.4% | 33.5% | 86.7% | 85.8% | 85.7% | 84.8% | 83.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 46.9% | 40.0% | 36.2% | 33.5% | 33.5% | 81.1% | 81.9% | 83.5% | 81.7% | 84.1%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 41.6% | 39.3% | 38.5% | 36.2% | 33.7% | 63.8% | 71.9% | 77.0% | 78.1% | 78.8%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 25.8% | 23.9% | 22.1% | 20.4% | 19.4% | 83.5% | 83.0% | 81.9% | 80.1% | 80.5%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.8% | 27.7% | 23.6% | 22.1% | 21.5% | 79.8% | 81.6% | 81.5% | 81.8% | 82.1%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 27.7% | 24.5% | 23.4% | 21.7% | 21.2% | 62.3% | 69.5% | 73.0% | 73.4% | 76.2%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.2% | 94.5% | 93.8% | 93.9% | 93.8% | 95.1% | 95.9% | 95.2% | 95.8% | 95.3%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.4% | 92.5% | 93.0% | 93.0% | 93.4% | 93.2% | 93.7% | 94.2% | 94.2% | 94.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.6% | 90.8% | 91.5% | 92.0% | 92.5% | 88.5% | 91.5% | 92.3% | 92.8% | 93.4%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.2% | 58.6% | 54.3% | 52.8% | 50.4% | 87.8% | 88.4% | 88.6% | 88.4% | 87.7%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.0% | 57.3% | 54.3% | 51.9% | 50.7% | 82.5% | 83.1% | 84.1% | 84.6% | 84.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 58.2% | 56.3% | 52.6% | 51.4% | 49.5% | 68.2% | 72.6% | 76.7% | 79.2% | 80.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 41.8% | 38.8% | 35.7% | 33.7% | 31.5% | 86.9% | 85.1% | 84.6% | 83.7% | 83.1%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.6% | 39.3% | 38.1% | 35.3% | 32.0% | 80.1% | 82.2% | 82.4% | 81.9% | 82.0%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 42.0% | 39.6% | 36.0% | 35.1% | 33.0% | 63.0% | 71.5% | 73.6% | 76.7% | 75.9%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.1% | 23.0% | 21.7% | 19.8% | 19.1% | 83.3% | 82.1% | 81.1% | 79.6% | 79.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 31.1% | 25.8% | 24.0% | 21.3% | 20.4% | 79.8% | 80.9% | 81.4% | 80.7% | 80.3%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.2% | 24.4% | 22.4% | 21.7% | 21.1% | 60.5% | 68.3% | 72.0% | 76.1% | 75.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.5% | 93.4% | 93.8% | 93.5% | 93.8% | 94.7% | 95.3% | 95.2% | 94.9% | 94.7%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 90.2% | 91.9% | 92.2% | 91.9% | 91.7% | 91.5% | 92.9% | 93.6% | 93.1% | 93.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 83.0% | 87.5% | 87.9% | 89.5% | 90.3% | 84.3% | 88.2% | 89.3% | 90.7% | 91.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.1% | 56.8% | 55.2% | 51.6% | 51.6% | 87.9% | 87.6% | 87.6% | 86.2% | 85.8%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 61.0% | 55.6% | 53.7% | 50.0% | 50.5% | 79.8% | 81.8% | 84.0% | 83.1% | 83.1%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 53.6% | 53.0% | 51.6% | 49.2% | 48.1% | 64.2% | 70.7% | 74.5% | 75.6% | 77.9%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 42.0% | 39.4% | 35.5% | 33.8% | 32.0% | 85.6% | 84.4% | 82.5% | 83.5% | 81.8%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 44.6% | 39.4% | 36.3% | 34.2% | 33.3% | 79.4% | 80.0% | 81.2% | 81.7% | 80.6%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 38.2% | 36.1% | 35.6% | 33.2% | 31.5% | 60.4% | 68.1% | 71.2% | 74.0% | 73.9%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 24.9% | 24.0% | 21.7% | 20.1% | 18.5% | 82.8% | 82.6% | 80.9% | 81.0% | 79.7%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.8% | 26.3% | 24.7% | 21.5% | 20.7% | 78.9% | 79.9% | 80.2% | 79.8% | 80.7%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 24.7% | 23.7% | 21.1% | 20.9% | 20.1% | 59.0% | 66.5% | 70.2% | 71.8% | 72.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 92.8% | 93.2% | 92.8% | 93.8% | 92.8% | 94.0% | 94.1% | 94.0% | 94.1% | 94.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 89.4% | 89.5% | 89.7% | 90.2% | 90.7% | 90.4% | 90.9% | 90.5% | 90.9% | 91.3%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 79.5% | 82.3% | 84.6% | 86.7% | 86.8% | 80.7% | 83.3% | 85.3% | 87.6% | 87.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 59.8% | 56.7% | 54.1% | 50.8% | 51.2% | 86.6% | 86.1% | 86.0% | 84.7% | 84.8%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 59.8% | 53.8% | 51.5% | 50.5% | 48.2% | 77.5% | 80.2% | 80.5% | 81.5% | 81.6%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 47.8% | 48.2% | 48.5% | 46.7% | 45.3% | 60.6% | 67.0% | 71.0% | 72.9% | 74.5%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 40.9% | 38.1% | 36.0% | 34.0% | 31.7% | 85.1% | 84.8% | 83.2% | 81.7% | 79.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.6% | 38.9% | 36.1% | 33.9% | 32.2% | 77.5% | 79.5% | 80.6% | 79.4% | 79.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 34.2% | 34.0% | 33.1% | 32.3% | 31.1% | 56.3% | 63.0% | 69.5% | 71.5% | 73.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.3% | 24.6% | 21.1% | 20.7% | 19.2% | 82.7% | 82.5% | 80.5% | 78.1% | 77.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.2% | 26.0% | 22.7% | 21.4% | 20.0% | 76.7% | 79.8% | 79.2% | 79.2% | 78.2%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 22.5% | 22.2% | 22.1% | 20.6% | 20.2% | 57.1% | 64.0% | 67.4% | 69.8% | 69.7%

Table E7 Absolute bias in the estimated slope, with no correction for publication bias (from 1-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | -0.002 | 0.000 | -0.001 | 0.001 | -0.002 | -0.002 | 0.000 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.008 | -0.005 | -0.004 | -0.001 | -0.003 | -0.009 | -0.005 | -0.004 | -0.001 | -0.003
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.030 | -0.015 | -0.009 | -0.009 | -0.003 | -0.030 | -0.015 | -0.010 | -0.009 | -0.003
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.000 | -0.007 | 0.003 | 0.001 | -0.004 | 0.000 | -0.008 | -0.002 | 0.002 | -0.004
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.019 | -0.008 | -0.005 | -0.007 | -0.002 | -0.019 | -0.011 | -0.011 | -0.006 | -0.004
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.040 | -0.020 | -0.020 | -0.012 | -0.009 | -0.039 | -0.022 | -0.019 | -0.011 | -0.010
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.019 | 0.008 | 0.001 | -0.003 | 0.007 | 0.010 | 0.002 | -0.003 | 0.001 | 0.002
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.018 | -0.016 | -0.017 | -0.008 | -0.003 | -0.017 | -0.014 | -0.012 | -0.010 | -0.010
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.033 | -0.022 | -0.021 | -0.020 | -0.022 | -0.027 | -0.027 | -0.019 | -0.020 | -0.018
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.008 | 0.014 | 0.008 | -0.021 | -0.003 | -0.009 | 0.010 | -0.010 | -0.004 | 0.001
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.020 | -0.002 | -0.020 | -0.013 | 0.004 | -0.008 | -0.011 | -0.025 | -0.012 | -0.007
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.009 | -0.009 | -0.026 | -0.006 | -0.008 | -0.028 | -0.018 | -0.027 | -0.020 | -0.009
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.002 | 0.001 | 0.001 | -0.001 | 0.000 | -0.001 | 0.000 | 0.001 | -0.001 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.018 | -0.007 | -0.004 | -0.004 | -0.002 | -0.019 | -0.008 | -0.005 | -0.004 | -0.003
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.047 | -0.023 | -0.014 | -0.011 | -0.008 | -0.047 | -0.024 | -0.014 | -0.011 | -0.009
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | -0.006 | -0.001 | -0.001 | 0.001 | 0.001 | -0.003 | 0.001 | 0.000 | -0.004
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.018 | -0.017 | -0.015 | -0.013 | -0.004 | -0.019 | -0.016 | -0.016 | -0.012 | -0.007
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.047 | -0.036 | -0.025 | -0.021 | -0.017 | -0.049 | -0.036 | -0.026 | -0.025 | -0.018
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.006 | 0.001 | -0.003 | 0.003 | -0.005 | -0.006 | 0.003 | -0.004 | -0.001 | 0.003
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.021 | -0.018 | -0.013 | -0.021 | -0.010 | -0.024 | -0.021 | -0.013 | -0.022 | -0.015
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.046 | -0.039 | -0.033 | -0.017 | -0.021 | -0.047 | -0.039 | -0.030 | -0.022 | -0.025
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.018 | 0.023 | -0.021 | 0.002 | -0.006 | 0.020 | 0.009 | -0.001 | 0.012 | 0.000
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.023 | -0.011 | -0.020 | -0.017 | -0.002 | -0.023 | -0.020 | -0.017 | -0.023 | -0.014
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.036 | -0.041 | -0.038 | -0.030 | -0.017 | -0.037 | -0.037 | -0.031 | -0.036 | -0.020
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | -0.001 | -0.001 | -0.002 | 0.001 | -0.001 | -0.001 | -0.001 | -0.002 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.027 | -0.015 | -0.011 | -0.008 | -0.007 | -0.028 | -0.015 | -0.011 | -0.008 | -0.008
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.083 | -0.045 | -0.031 | -0.021 | -0.016 | -0.084 | -0.045 | -0.032 | -0.022 | -0.017
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.003 | 0.006 | -0.001 | -0.001 | 0.001 | 0.002 | 0.007 | -0.001 | -0.002 | 0.001
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.043 | -0.027 | -0.027 | -0.017 | -0.013 | -0.044 | -0.037 | -0.031 | -0.024 | -0.018
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.080 | -0.060 | -0.049 | -0.041 | -0.030 | -0.081 | -0.061 | -0.053 | -0.049 | -0.037
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.006 | -0.005 | -0.012 | -0.002 | -0.008 | 0.000 | -0.001 | -0.005 | -0.004 | -0.005
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.044 | -0.052 | -0.035 | -0.037 | -0.024 | -0.046 | -0.046 | -0.040 | -0.039 | -0.026
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.073 | -0.062 | -0.054 | -0.043 | -0.049 | -0.081 | -0.062 | -0.062 | -0.052 | -0.048
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.003 | 0.005 | -0.009 | -0.001 | 0.001 | 0.001 | 0.003 | -0.005 | -0.011 | -0.006
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.059 | -0.040 | -0.029 | -0.038 | -0.029 | -0.057 | -0.041 | -0.040 | -0.037 | -0.032
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.100 | -0.077 | -0.057 | -0.061 | -0.037 | -0.092 | -0.082 | -0.066 | -0.053 | -0.048
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.002 | 0.001 | 0.000 | 0.001 | 0.000 | 0.002 | 0.001 | 0.000 | 0.001
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.053 | -0.030 | -0.023 | -0.016 | -0.012 | -0.055 | -0.031 | -0.024 | -0.017 | -0.013
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.168 | -0.088 | -0.056 | -0.039 | -0.029 | -0.169 | -0.089 | -0.057 | -0.040 | -0.030
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.004 | -0.003 | -0.001 | -0.004 | 0.007 | -0.004 | -0.002 | -0.001 | 0.003 | 0.005
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.088 | -0.062 | -0.042 | -0.040 | -0.025 | -0.093 | -0.073 | -0.049 | -0.050 | -0.038
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.165 | -0.126 | -0.097 | -0.082 | -0.066 | -0.167 | -0.128 | -0.104 | -0.092 | -0.077
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.001 | 0.012 | 0.002 | -0.007 | -0.009 | 0.000 | 0.007 | 0.003 | -0.006 | -0.002
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.099 | -0.064 | -0.064 | -0.060 | -0.044 | -0.105 | -0.081 | -0.075 | -0.065 | -0.055
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.165 | -0.140 | -0.114 | -0.094 | -0.080 | -0.165 | -0.140 | -0.117 | -0.101 | -0.093
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.015 | -0.016 | -0.006 | -0.002 | -0.010 | 0.009 | -0.013 | -0.002 | 0.000 | -0.006
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.128 | -0.081 | -0.087 | -0.076 | -0.061 | -0.127 | -0.094 | -0.084 | -0.079 | -0.066
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.164 | -0.130 | -0.123 | -0.109 | -0.101 | -0.160 | -0.125 | -0.128 | -0.114 | -0.100
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | 0.000 | -0.002 | 0.002 | 0.001 | 0.000 | 0.000 | -0.003 | 0.002 | 0.000
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.080 | -0.045 | -0.031 | -0.024 | -0.018 | -0.083 | -0.047 | -0.032 | -0.025 | -0.019
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.219 | -0.126 | -0.083 | -0.057 | -0.042 | -0.221 | -0.129 | -0.085 | -0.059 | -0.043
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.005 | -0.004 | 0.001 | 0.002 | 0.000 | -0.003 | -0.003 | 0.003 | 0.001 | 0.000
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.130 | -0.090 | -0.064 | -0.049 | -0.043 | -0.134 | -0.104 | -0.080 | -0.066 | -0.058
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.242 | -0.178 | -0.141 | -0.114 | -0.090 | -0.243 | -0.186 | -0.152 | -0.130 | -0.107
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.005 | -0.007 | 0.008 | 0.001 | 0.008 | 0.000 | -0.005 | 0.002 | -0.005 | -0.001
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.156 | -0.109 | -0.096 | -0.072 | -0.054 | -0.156 | -0.123 | -0.115 | -0.090 | -0.074
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.246 | -0.192 | -0.173 | -0.142 | -0.129 | -0.248 | -0.205 | -0.179 | -0.154 | -0.138
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.018 | 0.007 | 0.002 | 0.004 | 0.009 | -0.008 | 0.006 | 0.004 | 0.002 | 0.002
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.161 | -0.130 | -0.110 | -0.083 | -0.076 | -0.180 | -0.139 | -0.117 | -0.104 | -0.087
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.246 | -0.197 | -0.179 | -0.155 | -0.140 | -0.246 | -0.210 | -0.185 | -0.154 | -0.150

Table E8 Absolute bias in the estimated slope, with R studies imputed (from 1-dimensional algorithmic variant

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | -0.001 | 0.000 | 0.000 | 0.002 | -0.002 | -0.001 | 0.000 | 0.000
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.008 | -0.003 | -0.002 | 0.001 | -0.001 | -0.007 | -0.002 | -0.002 | 0.001 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.016 | -0.009 | -0.007 | -0.006 | 0.001 | -0.015 | -0.009 | -0.007 | -0.006 | 0.001
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | -0.006 | 0.003 | 0.002 | -0.004 | 0.000 | -0.006 | -0.001 | 0.003 | -0.003
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.014 | -0.006 | -0.003 | -0.004 | 0.002 | -0.011 | -0.005 | -0.006 | 0.000 | 0.003
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.028 | -0.011 | -0.012 | -0.006 | -0.005 | -0.026 | -0.010 | -0.009 | -0.002 | -0.001
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.014 | 0.009 | 0.001 | -0.001 | 0.008 | 0.008 | 0.005 | 0.000 | 0.005 | 0.004
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.018 | -0.013 | -0.011 | -0.004 | -0.002 | -0.009 | -0.006 | -0.003 | 0.002 | -0.003
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.024 | -0.017 | -0.017 | -0.014 | -0.018 | -0.018 | -0.017 | -0.012 | -0.010 | -0.010
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.007 | 0.018 | 0.007 | -0.020 | -0.003 | -0.010 | 0.014 | -0.007 | -0.004 | 0.003
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.006 | -0.004 | -0.019 | -0.012 | 0.009 | 0.000 | -0.006 | -0.023 | -0.004 | 0.000
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.008 | -0.004 | -0.014 | -0.003 | -0.005 | -0.021 | -0.005 | -0.015 | -0.010 | 0.006
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | 0.002 | 0.002 | 0.000 | 0.000 | 0.000 | 0.002 | 0.002 | 0.000 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.014 | -0.003 | -0.001 | -0.001 | 0.000 | -0.014 | -0.003 | -0.001 | -0.002 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.027 | -0.015 | -0.009 | -0.007 | -0.004 | -0.025 | -0.014 | -0.009 | -0.007 | -0.004
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | -0.006 | -0.001 | -0.001 | 0.001 | 0.003 | -0.002 | 0.003 | 0.001 | -0.002
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.009 | -0.011 | -0.011 | -0.010 | -0.002 | -0.006 | -0.004 | -0.007 | -0.004 | -0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.033 | -0.029 | -0.017 | -0.011 | -0.009 | -0.032 | -0.024 | -0.013 | -0.011 | -0.005
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.008 | 0.002 | -0.003 | 0.002 | -0.004 | -0.003 | 0.006 | 0.000 | 0.001 | 0.005
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.013 | -0.013 | -0.004 | -0.016 | -0.004 | -0.012 | -0.008 | -0.002 | -0.012 | -0.004
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.034 | -0.031 | -0.021 | -0.008 | -0.012 | -0.032 | -0.028 | -0.014 | -0.008 | -0.009
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.024 | 0.021 | -0.018 | 0.007 | -0.007 | 0.034 | 0.015 | 0.003 | 0.017 | 0.004
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.017 | 0.003 | -0.017 | -0.005 | 0.002 | -0.009 | 0.001 | -0.002 | -0.010 | -0.008
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.026 | -0.028 | -0.032 | -0.012 | -0.015 | -0.022 | -0.022 | -0.017 | -0.017 | -0.005
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.001 | 0.000 | -0.001 | 0.001 | 0.002 | 0.000 | 0.000 | -0.001 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.021 | -0.008 | -0.005 | -0.004 | -0.004 | -0.017 | -0.007 | -0.004 | -0.003 | -0.003
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.047 | -0.027 | -0.019 | -0.012 | -0.008 | -0.045 | -0.025 | -0.018 | -0.012 | -0.007
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.002 | 0.007 | 0.000 | -0.001 | 0.002 | 0.004 | 0.011 | 0.002 | 0.001 | 0.004
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.030 | -0.020 | -0.018 | -0.009 | -0.006 | -0.023 | -0.019 | -0.013 | -0.005 | -0.002
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.057 | -0.041 | -0.035 | -0.030 | -0.020 | -0.051 | -0.032 | -0.029 | -0.025 | -0.014
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.002 | -0.003 | -0.011 | 0.000 | -0.006 | 0.006 | 0.005 | 0.003 | 0.002 | -0.001
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.029 | -0.035 | -0.024 | -0.029 | -0.013 | -0.021 | -0.019 | -0.016 | -0.020 | -0.007
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.051 | -0.036 | -0.034 | -0.030 | -0.034 | -0.049 | -0.023 | -0.031 | -0.022 | -0.021
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.001 | 0.011 | -0.005 | 0.002 | 0.005 | 0.009 | 0.012 | 0.002 | -0.002 | 0.002
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.045 | -0.022 | -0.016 | -0.030 | -0.024 | -0.035 | -0.010 | -0.019 | -0.015 | -0.010
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.087 | -0.060 | -0.036 | -0.042 | -0.021 | -0.067 | -0.056 | -0.031 | -0.021 | -0.018
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.002 | 0.003 | 0.002 | 0.001 | 0.002 | 0.003 | 0.004 | 0.003 | 0.002 | 0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.041 | -0.019 | -0.013 | -0.007 | -0.004 | -0.036 | -0.015 | -0.011 | -0.005 | -0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.100 | -0.056 | -0.035 | -0.022 | -0.015 | -0.096 | -0.054 | -0.033 | -0.020 | -0.012
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.003 | -0.002 | 0.000 | -0.003 | 0.008 | 0.003 | 0.004 | 0.004 | 0.009 | 0.010
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.067 | -0.045 | -0.029 | -0.026 | -0.012 | -0.055 | -0.037 | -0.014 | -0.019 | -0.007
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.113 | -0.082 | -0.065 | -0.054 | -0.042 | -0.101 | -0.065 | -0.050 | -0.044 | -0.031
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.001 | 0.014 | 0.003 | -0.007 | -0.007 | 0.009 | 0.019 | 0.013 | 0.003 | 0.008
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.079 | -0.045 | -0.047 | -0.043 | -0.030 | -0.064 | -0.039 | -0.033 | -0.026 | -0.015
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.119 | -0.099 | -0.080 | -0.060 | -0.049 | -0.095 | -0.077 | -0.059 | -0.042 | -0.035
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.012 | -0.020 | -0.002 | 0.000 | -0.002 | 0.022 | -0.002 | 0.012 | 0.012 | 0.007
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.099 | -0.059 | -0.064 | -0.052 | -0.041 | -0.071 | -0.053 | -0.034 | -0.033 | -0.018
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.128 | -0.090 | -0.085 | -0.067 | -0.063 | -0.103 | -0.063 | -0.068 | -0.051 | -0.041
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.002 | -0.001 | 0.004 | 0.002 | 0.004 | 0.004 | 0.000 | 0.005 | 0.002
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.061 | -0.029 | -0.017 | -0.010 | -0.006 | -0.054 | -0.022 | -0.011 | -0.006 | -0.003
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.139 | -0.083 | -0.054 | -0.033 | -0.018 | -0.134 | -0.078 | -0.047 | -0.028 | -0.013
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.004 | -0.002 | 0.002 | 0.004 | 0.003 | 0.008 | 0.008 | 0.013 | 0.009 | 0.007
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.097 | -0.069 | -0.042 | -0.028 | -0.026 | -0.072 | -0.051 | -0.029 | -0.018 | -0.012
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.172 | -0.121 | -0.089 | -0.072 | -0.057 | -0.152 | -0.101 | -0.070 | -0.055 | -0.041
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.007 | -0.007 | 0.008 | 0.006 | 0.011 | 0.015 | 0.010 | 0.017 | 0.010 | 0.013
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.117 | -0.076 | -0.070 | -0.046 | -0.031 | -0.088 | -0.054 | -0.055 | -0.026 | -0.017
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.179 | -0.135 | -0.116 | -0.094 | -0.081 | -0.154 | -0.113 | -0.086 | -0.071 | -0.052
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.016 | 0.012 | 0.004 | 0.007 | 0.012 | 0.016 | 0.029 | 0.025 | 0.022 | 0.025
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.124 | -0.092 | -0.076 | -0.059 | -0.050 | -0.104 | -0.069 | -0.047 | -0.035 | -0.023
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.193 | -0.138 | -0.118 | -0.101 | -0.082 | -0.154 | -0.116 | -0.090 | -0.065 | -0.059

Table E9 Absolute bias in the estimated slope, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.002 | -0.002 | 0.000 | 0.000 | 0.001 | -0.001 | -0.001 | 0.000 | 0.000
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.008 | -0.004 | -0.003 | 0.000 | -0.002 | -0.008 | -0.003 | -0.003 | 0.000 | -0.002
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.018 | -0.010 | -0.007 | -0.007 | -0.001 | -0.017 | -0.010 | -0.007 | -0.007 | 0.000
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.000 | -0.004 | 0.002 | 0.002 | -0.004 | 0.002 | -0.004 | -0.001 | 0.005 | -0.002
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.016 | -0.007 | -0.004 | -0.004 | 0.000 | -0.012 | -0.007 | -0.006 | -0.001 | 0.002
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.031 | -0.013 | -0.014 | -0.007 | -0.006 | -0.029 | -0.012 | -0.010 | -0.002 | -0.003
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.014 | 0.006 | 0.002 | -0.001 | 0.009 | 0.008 | 0.006 | 0.003 | 0.007 | 0.006
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.017 | -0.014 | -0.012 | -0.006 | -0.004 | -0.010 | -0.007 | -0.003 | 0.000 | -0.005
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.029 | -0.018 | -0.017 | -0.017 | -0.019 | -0.021 | -0.018 | -0.013 | -0.014 | -0.012
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.006 | 0.018 | 0.002 | -0.023 | 0.000 | -0.006 | 0.018 | -0.008 | -0.002 | 0.008
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.011 | -0.006 | -0.021 | -0.011 | 0.007 | -0.003 | -0.009 | -0.025 | -0.005 | -0.003
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.012 | -0.005 | -0.019 | -0.005 | -0.008 | -0.025 | -0.008 | -0.018 | -0.014 | 0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.002 | 0.001 | 0.002 | 0.000 | -0.001 | -0.001 | 0.001 | 0.003 | 0.000 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.014 | -0.005 | -0.003 | -0.002 | -0.001 | -0.014 | -0.005 | -0.002 | -0.003 | -0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.030 | -0.016 | -0.011 | -0.009 | -0.006 | -0.027 | -0.015 | -0.011 | -0.008 | -0.006
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | -0.004 | -0.002 | 0.002 | 0.002 | 0.005 | 0.000 | 0.003 | 0.005 | -0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.011 | -0.012 | -0.011 | -0.010 | -0.003 | -0.008 | -0.005 | -0.007 | -0.004 | -0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.036 | -0.031 | -0.018 | -0.014 | -0.011 | -0.034 | -0.026 | -0.014 | -0.013 | -0.007
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.006 | 0.004 | -0.004 | 0.004 | -0.002 | 0.000 | 0.008 | 0.002 | 0.004 | 0.008
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.016 | -0.016 | -0.007 | -0.015 | -0.006 | -0.016 | -0.010 | -0.002 | -0.013 | -0.006
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.035 | -0.034 | -0.026 | -0.008 | -0.014 | -0.033 | -0.030 | -0.018 | -0.010 | -0.011
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.022 | 0.026 | -0.018 | 0.007 | -0.009 | 0.032 | 0.018 | 0.007 | 0.021 | 0.006
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.017 | 0.002 | -0.016 | -0.011 | -0.001 | -0.008 | -0.002 | -0.004 | -0.014 | -0.010
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.029 | -0.035 | -0.034 | -0.020 | -0.014 | -0.027 | -0.028 | -0.019 | -0.022 | -0.006
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.001 | -0.001 | -0.002 | 0.002 | 0.002 | 0.001 | 0.001 | -0.001 | 0.003
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.021 | -0.010 | -0.008 | -0.005 | -0.005 | -0.018 | -0.009 | -0.007 | -0.005 | -0.004
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.050 | -0.029 | -0.021 | -0.015 | -0.011 | -0.048 | -0.027 | -0.021 | -0.015 | -0.010
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.002 | 0.008 | 0.001 | 0.001 | 0.004 | 0.005 | 0.016 | 0.008 | 0.007 | 0.009
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.032 | -0.021 | -0.019 | -0.010 | -0.006 | -0.024 | -0.020 | -0.015 | -0.007 | -0.003
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.061 | -0.044 | -0.037 | -0.031 | -0.022 | -0.055 | -0.035 | -0.030 | -0.027 | -0.016
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.005 | -0.002 | -0.011 | 0.001 | -0.001 | 0.012 | 0.011 | 0.009 | 0.010 | 0.006
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.033 | -0.036 | -0.026 | -0.029 | -0.015 | -0.024 | -0.021 | -0.018 | -0.021 | -0.008
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.057 | -0.042 | -0.042 | -0.034 | -0.038 | -0.055 | -0.028 | -0.037 | -0.027 | -0.026
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.003 | 0.009 | -0.003 | 0.005 | 0.002 | 0.015 | 0.020 | 0.005 | 0.006 | 0.011
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.048 | -0.026 | -0.015 | -0.033 | -0.024 | -0.037 | -0.013 | -0.019 | -0.019 | -0.014
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.090 | -0.068 | -0.041 | -0.053 | -0.026 | -0.073 | -0.063 | -0.038 | -0.031 | -0.026
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.003 | 0.002 | 0.001 | 0.002 | 0.004 | 0.006 | 0.006 | 0.004 | 0.005
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.042 | -0.021 | -0.016 | -0.010 | -0.006 | -0.038 | -0.018 | -0.013 | -0.009 | -0.004
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.108 | -0.060 | -0.038 | -0.026 | -0.018 | -0.103 | -0.058 | -0.036 | -0.024 | -0.016
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.002 | 0.000 | 0.002 | 0.001 | 0.011 | 0.009 | 0.014 | 0.013 | 0.021 | 0.023
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.067 | -0.046 | -0.031 | -0.027 | -0.012 | -0.056 | -0.039 | -0.019 | -0.020 | -0.008
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.121 | -0.093 | -0.071 | -0.061 | -0.047 | -0.109 | -0.075 | -0.058 | -0.052 | -0.038
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.000 | 0.018 | 0.008 | 0.000 | -0.003 | 0.017 | 0.030 | 0.027 | 0.018 | 0.021
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.083 | -0.051 | -0.052 | -0.046 | -0.032 | -0.070 | -0.045 | -0.039 | -0.028 | -0.018
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.128 | -0.111 | -0.089 | -0.069 | -0.058 | -0.108 | -0.089 | -0.069 | -0.052 | -0.047
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.019 | -0.017 | -0.001 | 0.003 | 0.001 | 0.031 | 0.008 | 0.024 | 0.023 | 0.021
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.110 | -0.065 | -0.069 | -0.053 | -0.045 | -0.082 | -0.060 | -0.043 | -0.039 | -0.026
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.137 | -0.103 | -0.104 | -0.083 | -0.076 | -0.115 | -0.078 | -0.083 | -0.066 | -0.055
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.003 | 0.000 | 0.005 | 0.004 | 0.007 | 0.008 | 0.006 | 0.011 | 0.009
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.060 | -0.030 | -0.019 | -0.013 | -0.008 | -0.055 | -0.024 | -0.013 | -0.008 | -0.004
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.148 | -0.086 | -0.056 | -0.035 | -0.021 | -0.143 | -0.081 | -0.051 | -0.031 | -0.017
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.000 | 0.001 | 0.008 | 0.011 | 0.008 | 0.019 | 0.022 | 0.030 | 0.029 | 0.026
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.101 | -0.069 | -0.044 | -0.029 | -0.025 | -0.078 | -0.054 | -0.031 | -0.021 | -0.013
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.184 | -0.132 | -0.100 | -0.080 | -0.062 | -0.164 | -0.113 | -0.083 | -0.066 | -0.049
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.001 | -0.002 | 0.011 | 0.011 | 0.017 | 0.030 | 0.025 | 0.032 | 0.029 | 0.036
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.124 | -0.081 | -0.072 | -0.049 | -0.033 | -0.094 | -0.061 | -0.061 | -0.032 | -0.022
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.194 | -0.152 | -0.130 | -0.107 | -0.094 | -0.169 | -0.132 | -0.102 | -0.086 | -0.068
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.016 | 0.016 | 0.011 | 0.015 | 0.019 | 0.030 | 0.043 | 0.042 | 0.044 | 0.046
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.131 | -0.100 | -0.083 | -0.066 | -0.055 | -0.113 | -0.074 | -0.057 | -0.046 | -0.029
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.211 | -0.160 | -0.140 | -0.118 | -0.104 | -0.173 | -0.137 | -0.112 | -0.084 | -0.083

Table E10 Coverage probability of the estimated slope, with no correction for publication

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.1% | 95.2% | 94.9% | 95.0% | 95.4% | 96.4% | 96.3% | 95.8% | 96.2% | 96.3%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.9% | 95.4% | 95.6% | 95.3% | 95.0% | 96.2% | 95.9% | 96.1% | 95.8% | 95.3%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 95.9% | 94.9% | 95.1% | 95.2% | 94.8% | 96.3% | 95.3% | 95.4% | 95.3% | 95.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.0% | 61.4% | 58.2% | 56.1% | 54.9% | 92.3% | 92.4% | 93.1% | 93.5% | 93.6%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 70.7% | 64.6% | 60.9% | 58.0% | 55.6% | 90.1% | 90.6% | 92.0% | 92.8% | 93.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 82.8% | 71.4% | 64.9% | 61.4% | 57.6% | 90.4% | 88.6% | 89.6% | 91.7% | 92.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.8% | 41.4% | 39.0% | 39.0% | 35.9% | 92.7% | 93.0% | 93.0% | 93.6% | 93.8%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 54.9% | 47.5% | 42.6% | 39.6% | 38.3% | 91.9% | 93.3% | 93.3% | 94.0% | 94.3%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 68.0% | 55.2% | 48.2% | 45.0% | 41.6% | 89.9% | 92.0% | 92.8% | 93.2% | 94.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.8% | 26.2% | 24.5% | 22.3% | 22.2% | 92.3% | 92.9% | 93.6% | 93.3% | 94.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 37.6% | 31.9% | 27.0% | 25.4% | 23.6% | 92.9% | 93.2% | 93.4% | 94.1% | 94.1%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 47.7% | 38.4% | 32.6% | 29.3% | 26.2% | 90.9% | 93.9% | 93.8% | 94.1% | 93.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.2% | 95.2% | 95.1% | 95.2% | 95.5% | 96.2% | 96.6% | 96.1% | 96.2% | 96.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.8% | 95.5% | 95.7% | 95.5% | 95.5% | 96.1% | 95.8% | 96.0% | 95.9% | 95.8%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 96.0% | 95.2% | 94.4% | 95.1% | 94.9% | 96.4% | 95.6% | 94.7% | 95.3% | 95.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.2% | 60.0% | 56.7% | 56.9% | 53.7% | 92.4% | 93.2% | 92.9% | 93.6% | 93.4%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 71.3% | 64.3% | 59.8% | 56.5% | 54.3% | 89.8% | 90.0% | 91.5% | 92.2% | 93.2%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 82.6% | 71.3% | 63.7% | 61.2% | 57.9% | 90.1% | 88.1% | 89.0% | 91.6% | 91.9%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.6% | 41.3% | 39.7% | 37.3% | 35.9% | 93.1% | 93.2% | 93.6% | 94.0% | 94.5%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 54.7% | 46.8% | 42.0% | 39.9% | 38.9% | 91.3% | 92.7% | 93.5% | 93.4% | 94.1%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 67.1% | 54.4% | 48.7% | 45.9% | 41.2% | 90.0% | 91.1% | 92.6% | 93.5% | 93.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.6% | 25.4% | 25.0% | 22.8% | 20.9% | 93.1% | 93.0% | 93.2% | 93.5% | 93.7%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 37.1% | 31.9% | 29.0% | 27.0% | 24.7% | 92.5% | 93.6% | 94.0% | 93.6% | 94.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 47.7% | 36.9% | 32.4% | 28.9% | 26.5% | 90.7% | 92.6% | 93.5% | 93.0% | 93.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 95.0% | 94.6% | 95.0% | 95.0% | 95.4% | 96.3% | 95.7% | 96.3% | 95.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.5% | 95.1% | 95.3% | 95.4% | 95.3% | 95.8% | 95.5% | 95.8% | 95.9% | 95.6%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.7% | 94.8% | 95.1% | 94.5% | 95.1% | 95.2% | 95.0% | 95.3% | 94.9% | 95.4%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.0% | 62.3% | 58.0% | 56.8% | 53.2% | 91.8% | 93.7% | 93.0% | 94.2% | 93.8%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 71.3% | 64.9% | 59.7% | 57.5% | 55.3% | 89.4% | 90.0% | 91.5% | 92.5% | 92.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 81.3% | 71.8% | 64.9% | 61.0% | 58.0% | 89.7% | 88.4% | 89.1% | 90.1% | 91.5%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.4% | 41.9% | 39.1% | 36.3% | 35.4% | 92.5% | 93.6% | 93.3% | 94.0% | 93.3%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 55.0% | 46.9% | 43.5% | 39.7% | 38.0% | 91.5% | 92.6% | 93.6% | 93.6% | 93.5%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 67.2% | 54.8% | 46.6% | 42.4% | 40.5% | 89.5% | 90.4% | 92.7% | 93.1% | 93.4%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 29.0% | 26.1% | 24.1% | 21.9% | 22.3% | 92.4% | 93.2% | 92.6% | 93.2% | 93.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 37.2% | 31.5% | 27.9% | 26.0% | 23.7% | 92.5% | 92.9% | 93.6% | 94.3% | 93.0%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 47.7% | 37.9% | 31.7% | 29.9% | 27.1% | 90.6% | 93.0% | 93.4% | 93.9% | 93.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 95.3% | 95.1% | 95.4% | 94.7% | 96.1% | 96.1% | 96.6% | 96.4% | 96.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.9% | 95.0% | 95.0% | 94.9% | 95.0% | 94.5% | 95.3% | 95.5% | 95.2% | 95.4%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 89.5% | 91.3% | 92.8% | 93.0% | 94.4% | 90.2% | 91.7% | 93.2% | 93.3% | 94.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.7% | 59.6% | 59.1% | 55.6% | 53.5% | 92.5% | 93.1% | 93.8% | 93.7% | 94.2%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.2% | 63.9% | 59.9% | 57.6% | 54.1% | 87.8% | 89.9% | 91.9% | 92.0% | 92.7%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 76.2% | 66.4% | 61.6% | 58.1% | 55.7% | 84.8% | 83.9% | 85.4% | 86.8% | 88.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.1% | 41.8% | 39.0% | 37.3% | 35.6% | 92.7% | 92.9% | 93.9% | 93.4% | 93.6%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 53.6% | 45.9% | 42.3% | 37.7% | 37.1% | 90.1% | 91.8% | 92.3% | 93.0% | 93.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.3% | 51.9% | 46.4% | 41.9% | 39.2% | 86.2% | 88.3% | 90.3% | 90.7% | 91.4%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.1% | 26.6% | 23.8% | 22.3% | 22.6% | 91.2% | 93.4% | 93.4% | 93.6% | 93.3%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 37.7% | 31.1% | 27.7% | 25.8% | 24.2% | 92.2% | 92.9% | 92.9% | 93.1% | 94.0%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 45.0% | 37.3% | 32.3% | 28.5% | 27.4% | 89.4% | 91.5% | 92.8% | 92.4% | 92.7%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.9% | 95.2% | 95.4% | 95.0% | 94.6% | 96.2% | 96.1% | 96.2% | 95.8% | 95.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.1% | 94.8% | 94.2% | 94.7% | 94.9% | 93.8% | 94.9% | 94.5% | 95.0% | 95.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 85.7% | 86.9% | 89.1% | 91.1% | 92.5% | 86.5% | 87.3% | 89.6% | 91.2% | 92.7%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.6% | 59.3% | 58.4% | 54.9% | 54.9% | 92.5% | 92.3% | 93.4% | 93.3% | 94.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.0% | 61.3% | 58.9% | 56.1% | 54.1% | 85.5% | 87.8% | 89.6% | 90.5% | 91.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 68.1% | 61.3% | 57.6% | 55.7% | 54.0% | 79.1% | 78.3% | 80.6% | 82.7% | 84.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.4% | 42.4% | 40.3% | 36.2% | 34.9% | 93.0% | 93.5% | 93.8% | 93.7% | 93.3%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.7% | 45.3% | 40.3% | 39.7% | 37.6% | 88.6% | 89.9% | 90.6% | 92.3% | 92.3%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 59.8% | 50.3% | 44.9% | 40.5% | 37.7% | 82.8% | 83.9% | 86.0% | 87.8% | 88.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.8% | 26.5% | 24.3% | 23.1% | 21.1% | 92.5% | 93.0% | 93.9% | 93.3% | 94.1%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.1% | 31.0% | 28.0% | 25.8% | 23.7% | 90.5% | 92.1% | 92.2% | 92.7% | 92.8%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 45.4% | 35.7% | 31.0% | 28.3% | 25.8% | 87.8% | 89.2% | 90.1% | 91.3% | 90.7%

Table E11 Coverage probability of the estimated slope, with R studies imputed (from 1-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.7% | 94.9% | 94.7% | 94.8% | 95.3% | 96.0% | 96.1% | 95.6% | 96.1% | 96.2%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.5% | 92.9% | 93.7% | 93.5% | 93.0% | 94.3% | 93.7% | 94.4% | 94.2% | 94.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.4% | 93.0% | 92.8% | 92.3% | 92.3% | 94.7% | 93.4% | 93.5% | 92.9% | 93.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.8% | 61.4% | 58.0% | 55.9% | 54.9% | 91.2% | 91.8% | 92.5% | 92.8% | 92.9%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 67.1% | 62.5% | 58.9% | 55.8% | 54.8% | 85.8% | 86.2% | 87.6% | 88.6% | 89.1%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 79.4% | 67.2% | 62.0% | 57.7% | 53.9% | 87.1% | 85.0% | 84.7% | 86.3% | 86.4%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.7% | 41.6% | 38.4% | 38.7% | 35.8% | 90.4% | 91.1% | 91.0% | 92.3% | 92.8%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.0% | 45.0% | 41.3% | 38.1% | 36.5% | 85.7% | 87.7% | 87.8% | 87.7% | 88.3%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.9% | 49.9% | 44.3% | 41.0% | 37.6% | 85.1% | 84.6% | 85.1% | 86.5% | 86.3%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.3% | 26.0% | 24.6% | 22.5% | 22.4% | 89.0% | 90.2% | 91.1% | 91.2% | 91.8%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.1% | 29.2% | 25.4% | 24.6% | 22.4% | 85.2% | 86.3% | 87.0% | 86.4% | 86.8%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 44.4% | 34.4% | 29.0% | 26.0% | 23.4% | 84.7% | 85.5% | 85.5% | 84.8% | 85.0%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 95.0% | 94.9% | 94.9% | 95.4% | 96.1% | 96.4% | 96.0% | 96.0% | 96.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.3% | 93.1% | 93.8% | 93.7% | 94.2% | 94.0% | 93.7% | 94.4% | 94.4% | 95.1%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.7% | 92.4% | 90.9% | 92.7% | 92.6% | 95.0% | 93.2% | 91.8% | 93.4% | 93.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.1% | 59.8% | 56.4% | 56.7% | 53.8% | 91.2% | 92.5% | 92.2% | 93.0% | 92.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 67.6% | 62.0% | 57.7% | 55.2% | 53.2% | 86.1% | 86.4% | 87.4% | 88.6% | 89.8%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 79.3% | 67.2% | 61.1% | 58.2% | 56.1% | 87.9% | 84.2% | 84.7% | 86.6% | 86.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.6% | 41.5% | 39.5% | 37.6% | 35.6% | 90.5% | 91.2% | 92.1% | 92.4% | 93.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.4% | 44.3% | 39.4% | 38.1% | 37.6% | 85.6% | 86.1% | 86.6% | 86.9% | 88.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.7% | 50.2% | 44.1% | 42.3% | 37.9% | 84.7% | 84.8% | 85.3% | 86.3% | 86.2%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.4% | 25.7% | 24.8% | 23.1% | 21.0% | 89.8% | 90.1% | 90.5% | 90.9% | 91.5%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 33.8% | 30.1% | 27.2% | 24.4% | 23.2% | 86.2% | 86.3% | 87.0% | 87.3% | 87.3%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 44.0% | 33.1% | 29.9% | 26.7% | 23.3% | 84.2% | 84.6% | 85.6% | 85.5% | 85.6%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.8% | 94.7% | 94.3% | 94.8% | 94.9% | 95.1% | 96.1% | 95.6% | 96.3% | 95.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.9% | 92.8% | 93.2% | 93.5% | 94.1% | 93.8% | 93.5% | 94.0% | 94.2% | 95.3%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 93.8% | 92.8% | 92.5% | 92.0% | 92.5% | 94.3% | 93.4% | 93.1% | 92.9% | 93.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.5% | 62.3% | 58.0% | 56.5% | 53.1% | 90.8% | 92.9% | 92.5% | 93.6% | 93.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.2% | 62.3% | 57.9% | 56.3% | 53.7% | 85.7% | 86.4% | 87.9% | 88.8% | 88.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 78.5% | 68.5% | 61.5% | 57.6% | 56.0% | 87.0% | 85.0% | 85.3% | 86.4% | 86.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 46.1% | 42.3% | 39.2% | 36.5% | 35.5% | 90.4% | 91.8% | 91.9% | 92.6% | 92.2%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.5% | 44.1% | 41.7% | 38.4% | 36.2% | 85.2% | 86.4% | 86.4% | 88.2% | 87.6%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 62.3% | 50.8% | 43.2% | 39.3% | 38.2% | 84.6% | 84.6% | 85.5% | 85.9% | 85.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.6% | 25.9% | 24.1% | 21.7% | 22.0% | 89.3% | 90.6% | 90.5% | 91.2% | 91.5%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.7% | 29.2% | 26.2% | 24.1% | 23.0% | 86.0% | 85.7% | 86.7% | 87.3% | 86.5%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.9% | 33.8% | 29.2% | 27.4% | 24.3% | 83.9% | 85.1% | 84.3% | 86.3% | 85.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.5% | 94.8% | 94.7% | 94.9% | 94.7% | 95.8% | 95.9% | 96.3% | 96.2% | 96.1%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 90.9% | 92.2% | 92.6% | 93.4% | 93.5% | 92.0% | 93.6% | 93.9% | 94.0% | 94.3%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 90.6% | 89.5% | 89.8% | 90.6% | 92.2% | 91.5% | 90.7% | 91.5% | 92.1% | 93.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.4% | 59.6% | 59.2% | 55.4% | 53.2% | 91.0% | 92.6% | 93.2% | 92.8% | 93.5%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 66.8% | 61.4% | 57.9% | 56.3% | 53.1% | 84.4% | 86.8% | 88.5% | 88.3% | 89.5%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 75.1% | 65.3% | 59.3% | 56.3% | 53.8% | 84.2% | 83.4% | 84.0% | 84.7% | 86.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.6% | 41.7% | 39.1% | 37.1% | 35.6% | 90.7% | 91.0% | 91.7% | 91.9% | 92.2%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.1% | 42.8% | 40.0% | 37.3% | 35.9% | 85.0% | 86.3% | 87.0% | 87.7% | 88.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 61.6% | 48.3% | 44.2% | 38.8% | 37.0% | 83.8% | 84.1% | 85.4% | 85.7% | 85.5%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.8% | 26.5% | 23.5% | 22.1% | 22.1% | 88.7% | 90.3% | 90.8% | 91.6% | 91.3%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.0% | 29.3% | 26.1% | 24.9% | 23.2% | 86.7% | 86.1% | 86.5% | 86.9% | 88.3%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 41.8% | 34.3% | 29.1% | 26.2% | 24.3% | 83.6% | 84.8% | 85.2% | 85.5% | 86.0%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.1% | 94.9% | 95.1% | 94.8% | 94.5% | 95.4% | 95.8% | 95.8% | 95.7% | 95.7%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 89.4% | 91.4% | 91.1% | 92.3% | 93.4% | 91.7% | 93.3% | 93.0% | 93.3% | 94.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 88.2% | 86.5% | 87.6% | 88.4% | 89.7% | 89.2% | 88.6% | 89.9% | 91.4% | 91.5%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.3% | 59.3% | 58.4% | 54.9% | 54.6% | 91.3% | 91.6% | 92.4% | 92.8% | 94.0%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 65.4% | 58.3% | 56.9% | 55.1% | 53.5% | 84.3% | 86.1% | 87.3% | 88.8% | 89.4%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 69.1% | 62.0% | 57.0% | 55.2% | 53.0% | 81.5% | 81.3% | 82.8% | 84.6% | 86.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.0% | 42.3% | 40.3% | 36.0% | 34.9% | 91.0% | 91.5% | 92.0% | 92.1% | 91.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.6% | 43.5% | 39.3% | 38.3% | 36.2% | 85.4% | 85.6% | 86.1% | 88.0% | 88.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 58.2% | 48.6% | 43.0% | 39.5% | 36.3% | 81.5% | 82.5% | 84.8% | 85.8% | 85.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.6% | 26.5% | 24.3% | 23.1% | 20.7% | 89.7% | 90.0% | 90.8% | 90.7% | 91.8%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 33.5% | 28.7% | 26.1% | 23.2% | 22.0% | 84.3% | 85.6% | 86.2% | 86.5% | 86.7%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 42.0% | 32.5% | 27.8% | 25.2% | 24.3% | 83.2% | 83.9% | 84.1% | 84.9% | 84.5%

Table E12 Coverage probability of the estimated slope, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.1% | 94.6% | 94.3% | 94.4% | 94.8% | 95.3% | 96.0% | 95.5% | 95.7% | 96.2%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 94.6% | 93.7% | 93.8% | 93.8% | 93.3% | 95.2% | 94.3% | 94.6% | 94.4% | 93.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.7% | 94.1% | 93.7% | 93.2% | 93.4% | 95.1% | 94.4% | 94.5% | 93.6% | 94.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.3% | 61.3% | 57.8% | 55.5% | 55.2% | 90.2% | 90.2% | 90.7% | 91.3% | 90.6%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.2% | 63.2% | 59.5% | 56.4% | 55.0% | 86.4% | 87.1% | 87.9% | 88.4% | 89.2%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 80.5% | 70.5% | 63.9% | 60.1% | 55.9% | 88.1% | 86.0% | 86.2% | 87.6% | 88.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.4% | 41.0% | 38.3% | 38.4% | 35.8% | 88.7% | 88.2% | 89.0% | 89.8% | 90.2%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 53.3% | 46.8% | 41.6% | 38.4% | 37.7% | 86.9% | 89.0% | 88.2% | 88.4% | 88.7%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 66.4% | 53.6% | 46.8% | 43.5% | 39.8% | 86.5% | 86.8% | 87.2% | 88.1% | 88.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.3% | 25.8% | 24.0% | 21.8% | 21.7% | 87.3% | 88.0% | 89.0% | 88.9% | 89.1%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.6% | 30.9% | 25.9% | 25.2% | 22.9% | 86.8% | 87.7% | 88.1% | 88.1% | 87.5%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 46.4% | 36.6% | 31.4% | 27.9% | 25.3% | 86.4% | 88.0% | 88.0% | 87.0% | 87.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.3% | 94.7% | 94.5% | 94.7% | 94.6% | 95.7% | 95.9% | 95.7% | 95.7% | 96.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 94.1% | 93.8% | 94.2% | 93.9% | 94.2% | 94.8% | 94.3% | 94.8% | 94.6% | 94.9%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 95.2% | 93.2% | 92.7% | 93.5% | 93.1% | 95.5% | 94.0% | 93.6% | 94.2% | 94.0%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.2% | 59.6% | 56.5% | 56.7% | 53.8% | 89.7% | 90.4% | 90.5% | 91.4% | 91.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.4% | 62.9% | 59.5% | 56.5% | 54.2% | 87.1% | 86.8% | 87.8% | 88.6% | 89.5%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 81.4% | 70.1% | 63.5% | 60.3% | 57.2% | 88.9% | 86.1% | 86.2% | 87.7% | 87.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.3% | 40.9% | 39.1% | 37.0% | 35.3% | 89.3% | 89.5% | 89.1% | 90.3% | 90.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 53.2% | 45.6% | 41.0% | 38.2% | 38.1% | 85.9% | 87.2% | 87.7% | 88.0% | 89.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 65.8% | 53.3% | 46.3% | 44.8% | 39.9% | 86.3% | 86.4% | 86.9% | 87.8% | 88.0%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.6% | 24.9% | 24.5% | 22.4% | 21.1% | 88.0% | 88.1% | 87.9% | 87.9% | 88.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.6% | 30.7% | 28.7% | 25.3% | 23.6% | 86.8% | 87.5% | 88.3% | 88.1% | 87.7%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 46.8% | 35.7% | 31.3% | 27.9% | 25.6% | 86.2% | 86.6% | 87.3% | 86.9% | 88.3%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.3% | 94.1% | 94.0% | 94.4% | 94.5% | 94.8% | 95.6% | 95.4% | 96.0% | 95.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.5% | 93.3% | 93.5% | 93.6% | 93.9% | 94.2% | 94.1% | 94.3% | 94.4% | 94.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.2% | 93.6% | 93.5% | 92.7% | 93.5% | 94.5% | 93.9% | 93.9% | 93.3% | 94.1%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.3% | 61.7% | 57.8% | 56.7% | 53.6% | 89.6% | 90.9% | 90.8% | 91.7% | 91.7%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 70.2% | 63.5% | 59.6% | 56.8% | 54.1% | 86.8% | 86.8% | 88.6% | 89.0% | 88.9%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 79.5% | 70.3% | 63.4% | 59.7% | 56.9% | 87.8% | 86.4% | 86.4% | 87.1% | 87.1%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.9% | 42.1% | 38.6% | 36.0% | 35.0% | 88.2% | 89.7% | 89.7% | 89.8% | 89.5%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.9% | 46.1% | 42.6% | 38.3% | 37.0% | 86.6% | 87.5% | 87.6% | 88.4% | 87.8%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 65.0% | 53.1% | 45.5% | 41.1% | 39.6% | 86.2% | 86.1% | 87.5% | 87.2% | 87.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.3% | 25.8% | 23.6% | 21.9% | 21.4% | 87.7% | 87.9% | 87.4% | 88.5% | 88.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.4% | 30.5% | 26.8% | 24.6% | 23.4% | 87.1% | 86.9% | 87.5% | 88.0% | 87.3%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 46.4% | 36.7% | 30.9% | 29.0% | 26.1% | 85.4% | 87.5% | 87.1% | 87.8% | 87.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.8% | 94.1% | 94.0% | 94.1% | 94.2% | 95.2% | 95.2% | 95.7% | 95.2% | 95.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.5% | 92.6% | 92.5% | 93.4% | 93.3% | 92.4% | 93.7% | 93.7% | 94.4% | 93.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 91.5% | 91.1% | 91.1% | 91.6% | 92.6% | 92.1% | 91.7% | 92.3% | 92.8% | 93.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.5% | 58.7% | 59.2% | 55.5% | 53.1% | 89.9% | 90.7% | 91.6% | 90.1% | 91.1%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.0% | 62.5% | 59.3% | 56.6% | 53.6% | 85.5% | 87.2% | 88.9% | 88.4% | 89.0%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 76.3% | 67.1% | 61.0% | 57.9% | 55.7% | 84.7% | 83.7% | 84.9% | 85.5% | 87.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.1% | 41.1% | 38.5% | 36.6% | 35.0% | 88.5% | 88.7% | 89.3% | 89.3% | 89.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.9% | 44.5% | 40.5% | 37.9% | 36.7% | 85.9% | 87.7% | 87.6% | 88.3% | 88.2%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.0% | 50.7% | 45.9% | 41.4% | 38.3% | 84.9% | 85.4% | 87.0% | 86.7% | 87.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.8% | 25.4% | 23.1% | 21.6% | 21.8% | 86.5% | 88.7% | 88.3% | 88.5% | 88.5%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.1% | 30.3% | 26.4% | 25.8% | 23.5% | 87.6% | 87.0% | 87.6% | 87.9% | 88.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.3% | 36.4% | 30.7% | 27.4% | 26.3% | 85.4% | 86.8% | 87.5% | 87.4% | 87.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.2% | 93.7% | 94.0% | 94.1% | 93.6% | 94.7% | 94.7% | 95.0% | 94.9% | 94.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.3% | 92.2% | 91.7% | 91.9% | 92.7% | 92.8% | 93.2% | 93.0% | 93.0% | 93.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 88.6% | 87.8% | 89.2% | 89.8% | 90.3% | 89.4% | 89.0% | 90.0% | 91.1% | 91.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.2% | 58.6% | 57.7% | 54.1% | 53.4% | 89.9% | 89.6% | 90.4% | 90.0% | 91.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 66.9% | 59.1% | 57.7% | 55.7% | 53.2% | 85.0% | 85.5% | 87.0% | 88.3% | 88.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 69.9% | 62.3% | 58.4% | 55.9% | 53.6% | 81.7% | 81.2% | 82.5% | 84.1% | 84.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.8% | 40.9% | 39.8% | 35.6% | 34.3% | 88.9% | 89.4% | 89.7% | 89.0% | 88.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.6% | 44.3% | 39.4% | 38.2% | 37.1% | 85.9% | 86.3% | 86.9% | 87.6% | 88.2%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 59.0% | 50.0% | 44.4% | 40.1% | 36.5% | 81.6% | 83.2% | 85.2% | 86.0% | 86.0%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.0% | 25.6% | 24.0% | 23.0% | 20.9% | 87.8% | 87.7% | 88.1% | 87.8% | 88.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.2% | 29.9% | 27.1% | 23.9% | 22.3% | 85.5% | 87.0% | 86.9% | 87.3% | 87.9%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.4% | 34.1% | 30.1% | 27.4% | 25.6% | 84.0% | 85.1% | 85.8% | 86.4% | 86.1%

Table E13 Relative bias in the estimated slope, with no correction for publication bias (from 1-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 2.2% | -4.4% | -3.8% | -0.8% | -1.3% | 3.0% | -4.5% | -3.8% | -0.2% | -1.3%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -17.1% | -10.1% | -8.5% | -1.9% | -5.6% | -17.7% | -10.6% | -8.7% | -2.7% | -6.3%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -61.1% | -29.6% | -19.0% | -17.9% | -6.1% | -60.9% | -30.3% | -19.6% | -18.0% | -6.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.5% | -14.2% | 6.2% | 2.9% | -8.2% | -0.7% | -15.2% | -3.6% | 4.0% | -8.1%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -39.0% | -15.4% | -9.5% | -13.2% | -4.0% | -39.3% | -22.5% | -21.3% | -12.2% | -7.6%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -81.2% | -40.7% | -39.9% | -24.4% | -19.1% | -79.3% | -44.7% | -39.3% | -21.9% | -20.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 37.6% | 16.0% | 2.5% | -6.3% | 13.8% | 20.3% | 4.6% | -5.4% | 1.3% | 4.0%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -37.0% | -32.8% | -34.3% | -16.3% | -5.1% | -35.3% | -28.7% | -23.3% | -19.5% | -19.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -66.9% | -44.6% | -43.4% | -39.6% | -44.8% | -54.3% | -54.7% | -37.7% | -40.8% | -35.6%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -17.0% | 27.8% | 16.8% | -42.0% | -6.5% | -18.8% | 20.3% | -21.0% | -8.9% | 2.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -39.6% | -5.0% | -40.8% | -26.6% | 7.6% | -17.2% | -23.2% | -51.1% | -23.5% | -14.8%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -18.3% | -19.0% | -52.8% | -13.0% | -16.1% | -56.2% | -36.8% | -54.9% | -40.9% | -17.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -2.0% | 1.4% | 2.0% | -0.7% | -0.6% | -1.5% | 0.7% | 2.0% | -0.9% | -0.4%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -24.1% | -10.1% | -5.7% | -4.8% | -3.0% | -25.0% | -10.8% | -6.3% | -5.7% | -3.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -63.1% | -31.2% | -18.5% | -14.9% | -11.1% | -63.1% | -31.8% | -19.0% | -15.3% | -11.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.0% | -7.8% | -1.9% | -1.6% | 1.4% | 1.8% | -3.8% | 1.1% | 0.2% | -5.1%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -24.3% | -23.4% | -19.9% | -16.9% | -5.6% | -25.5% | -21.8% | -21.2% | -16.5% | -8.9%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -63.0% | -48.7% | -33.6% | -27.9% | -23.3% | -66.2% | -48.2% | -34.6% | -33.3% | -24.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -8.4% | 1.5% | -3.7% | 3.6% | -6.4% | -7.8% | 4.5% | -4.9% | -0.9% | 4.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -28.5% | -24.7% | -16.9% | -27.8% | -14.0% | -33.0% | -28.1% | -18.2% | -29.8% | -20.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -61.8% | -52.4% | -44.8% | -22.8% | -28.5% | -63.0% | -52.3% | -40.1% | -30.4% | -33.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 23.9% | 30.6% | -28.2% | 3.0% | -8.4% | 26.6% | 12.0% | -1.4% | 16.7% | -0.5%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -31.4% | -14.2% | -26.4% | -23.1% | -2.7% | -31.5% | -26.8% | -22.7% | -30.4% | -18.9%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -49.0% | -56.0% | -50.7% | -40.3% | -22.7% | -50.5% | -49.3% | -41.3% | -48.4% | -27.2%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.0% | -0.9% | -0.5% | -1.2% | 0.9% | -0.5% | -0.8% | -0.4% | -1.2% | 0.6%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.5% | -9.8% | -7.4% | -5.2% | -5.0% | -18.7% | -10.3% | -7.6% | -5.5% | -5.3%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -56.3% | -30.4% | -21.0% | -14.2% | -11.1% | -56.9% | -30.5% | -21.5% | -14.6% | -11.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 2.1% | 3.9% | -0.9% | -0.6% | 1.0% | 1.2% | 4.9% | -1.0% | -1.1% | 0.9%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -28.9% | -18.4% | -18.1% | -11.4% | -8.8% | -29.8% | -24.7% | -20.9% | -16.0% | -12.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -53.7% | -40.6% | -33.2% | -27.7% | -20.6% | -54.6% | -41.3% | -36.1% | -32.9% | -24.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.7% | -3.5% | -8.0% | -1.4% | -5.1% | 0.0% | -0.7% | -3.1% | -2.7% | -3.7%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -29.8% | -35.0% | -23.6% | -24.7% | -16.2% | -31.2% | -30.9% | -26.7% | -26.4% | -17.4%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -49.1% | -42.0% | -36.6% | -29.2% | -33.1% | -54.4% | -42.0% | -42.1% | -34.9% | -32.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -1.9% | 3.1% | -6.1% | -0.8% | 0.9% | 0.7% | 1.8% | -3.3% | -7.1% | -4.0%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -39.7% | -26.7% | -19.3% | -25.7% | -19.7% | -38.5% | -27.6% | -27.0% | -24.9% | -21.5%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -67.3% | -52.1% | -38.3% | -41.2% | -24.7% | -62.0% | -55.5% | -44.5% | -35.7% | -32.4%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.2% | 0.7% | 0.2% | 0.0% | 0.4% | 0.1% | 0.7% | 0.2% | 0.1% | 0.4%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -17.9% | -10.1% | -7.7% | -5.4% | -4.1% | -18.5% | -10.6% | -8.0% | -5.7% | -4.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -56.7% | -29.7% | -18.9% | -13.1% | -9.7% | -57.1% | -30.2% | -19.3% | -13.4% | -10.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -1.5% | -1.0% | -0.4% | -1.3% | 2.2% | -1.5% | -0.5% | -0.3% | 1.1% | 1.7%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -29.5% | -21.0% | -14.2% | -13.4% | -8.3% | -31.5% | -24.5% | -16.6% | -17.0% | -12.9%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -55.8% | -42.5% | -32.8% | -27.7% | -22.4% | -56.5% | -43.0% | -35.0% | -31.0% | -26.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.3% | 4.1% | 0.5% | -2.4% | -3.1% | 0.1% | 2.4% | 0.9% | -2.1% | -0.5%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -33.4% | -21.7% | -21.6% | -20.2% | -14.9% | -35.5% | -27.4% | -25.2% | -22.0% | -18.5%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -55.8% | -47.3% | -38.4% | -31.7% | -26.9% | -55.6% | -47.2% | -39.6% | -34.2% | -31.4%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 5.1% | -5.5% | -2.0% | -0.6% | -3.5% | 3.1% | -4.4% | -0.8% | 0.1% | -1.9%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -43.2% | -27.5% | -29.4% | -25.5% | -20.7% | -42.8% | -31.7% | -28.4% | -26.7% | -22.1%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -55.4% | -44.0% | -41.6% | -36.8% | -34.1% | -54.0% | -42.1% | -43.4% | -38.6% | -33.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.1% | 0.1% | -0.5% | 0.5% | 0.2% | -0.1% | 0.1% | -0.6% | 0.5% | 0.0%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.0% | -10.1% | -6.9% | -5.3% | -4.1% | -18.7% | -10.5% | -7.3% | -5.6% | -4.4%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -49.2% | -28.5% | -18.7% | -12.9% | -9.4% | -49.8% | -28.9% | -19.1% | -13.3% | -9.6%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -1.2% | -0.9% | 0.2% | 0.5% | 0.1% | -0.7% | -0.7% | 0.8% | 0.1% | 0.0%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -29.3% | -20.3% | -14.3% | -11.0% | -9.8% | -30.1% | -23.4% | -17.9% | -14.8% | -13.0%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -54.5% | -40.1% | -31.6% | -25.6% | -20.3% | -54.7% | -41.8% | -34.1% | -29.1% | -24.2%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -1.2% | -1.6% | 1.7% | 0.1% | 1.9% | 0.0% | -1.0% | 0.4% | -1.2% | -0.2%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -35.0% | -24.6% | -21.5% | -16.3% | -12.1% | -35.1% | -27.6% | -25.9% | -20.3% | -16.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -55.3% | -43.2% | -38.9% | -31.9% | -28.9% | -55.8% | -46.1% | -40.2% | -34.7% | -31.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -4.1% | 1.7% | 0.4% | 0.8% | 2.0% | -1.7% | 1.2% | 0.8% | 0.4% | 0.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -36.1% | -29.1% | -24.7% | -18.8% | -17.2% | -40.4% | -31.2% | -26.3% | -23.4% | -19.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -55.3% | -44.4% | -40.2% | -35.0% | -31.4% | -55.4% | -47.3% | -41.7% | -34.6% | -33.8%

Table E14 Relative bias in the estimated slope, with R studies imputed (from 1-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 2.8% | -3.8% | -2.5% | -0.6% | -1.0% | 4.9% | -3.8% | -1.6% | 0.0% | -0.6%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -15.6% | -5.4% | -4.5% | 2.5% | -2.1% | -14.7% | -4.7% | -3.6% | 2.6% | -2.5%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -31.8% | -18.8% | -15.0% | -12.6% | 1.3% | -30.4% | -18.1% | -14.6% | -12.0% | 2.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -1.0% | -11.3% | 5.6% | 3.5% | -7.9% | -0.4% | -12.3% | -2.5% | 6.9% | -6.7%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -27.7% | -12.1% | -6.7% | -7.6% | 3.1% | -23.2% | -10.7% | -12.8% | 0.3% | 6.9%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -56.4% | -22.7% | -23.4% | -11.2% | -10.5% | -51.9% | -21.0% | -19.0% | -3.4% | -2.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 28.6% | 18.5% | 2.3% | -1.5% | 15.8% | 16.7% | 10.3% | -0.4% | 9.5% | 8.7%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -37.2% | -26.8% | -22.1% | -7.9% | -3.3% | -18.6% | -12.9% | -6.6% | 4.6% | -6.7%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -49.2% | -35.2% | -34.1% | -27.8% | -37.3% | -37.5% | -34.5% | -23.9% | -19.4% | -21.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -14.9% | 35.8% | 13.5% | -40.0% | -5.3% | -19.2% | 28.8% | -15.1% | -8.0% | 6.5%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -13.1% | -7.9% | -37.7% | -23.6% | 18.4% | -0.1% | -12.4% | -46.7% | -7.7% | -0.9%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -15.5% | -8.6% | -28.3% | -6.0% | -10.8% | -42.2% | -10.1% | -30.1% | -20.7% | 11.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.6% | 2.4% | 2.5% | -0.1% | -0.5% | -0.4% | 2.2% | 2.8% | -0.1% | -0.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.5% | -4.5% | -1.9% | -1.3% | -0.3% | -18.5% | -3.7% | -1.3% | -2.4% | -0.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -36.3% | -20.6% | -12.3% | -9.8% | -5.3% | -33.4% | -19.2% | -12.4% | -9.5% | -5.8%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.1% | -7.7% | -1.1% | -1.1% | 1.4% | 4.6% | -2.4% | 4.2% | 2.0% | -3.4%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -11.8% | -15.4% | -14.7% | -14.1% | -3.2% | -8.6% | -5.1% | -9.2% | -4.9% | -1.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -44.9% | -39.1% | -22.9% | -15.5% | -11.9% | -43.2% | -32.5% | -17.7% | -14.4% | -6.2%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -11.2% | 2.6% | -3.6% | 2.6% | -5.6% | -4.6% | 8.0% | -0.2% | 1.8% | 7.0%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -17.0% | -17.9% | -6.0% | -21.7% | -5.2% | -15.8% | -10.9% | -2.1% | -16.5% | -6.0%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -45.2% | -41.4% | -27.8% | -10.2% | -16.4% | -43.5% | -37.3% | -18.4% | -10.5% | -11.9%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 32.0% | 28.0% | -23.9% | 9.6% | -8.9% | 45.9% | 20.0% | 3.8% | 23.4% | 5.1%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -23.0% | 4.7% | -23.1% | -7.3% | 2.5% | -11.5% | 1.9% | -3.3% | -13.7% | -10.7%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -35.5% | -37.6% | -43.3% | -16.8% | -19.6% | -29.3% | -29.3% | -23.2% | -23.4% | -7.4%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.0% | -0.4% | -0.3% | -0.8% | 1.0% | 1.2% | 0.1% | 0.1% | -0.6% | 0.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.1% | -5.1% | -3.3% | -2.5% | -2.5% | -11.6% | -4.8% | -2.7% | -2.2% | -2.2%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -31.6% | -18.4% | -12.6% | -8.4% | -5.4% | -30.3% | -16.9% | -12.1% | -7.9% | -5.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.1% | 4.6% | -0.2% | -0.6% | 1.4% | 2.9% | 7.5% | 1.3% | 0.4% | 2.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -20.1% | -13.4% | -12.3% | -6.2% | -3.8% | -15.4% | -12.5% | -8.7% | -3.4% | -1.3%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -38.2% | -27.3% | -23.8% | -19.9% | -13.4% | -34.3% | -21.8% | -19.6% | -16.6% | -9.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.4% | -2.3% | -7.6% | -0.1% | -4.2% | 4.1% | 3.3% | 1.7% | 1.0% | -0.9%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -19.7% | -23.5% | -16.1% | -19.4% | -8.8% | -14.4% | -12.6% | -10.7% | -13.4% | -4.4%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -34.2% | -24.1% | -22.7% | -20.3% | -22.7% | -33.0% | -15.3% | -20.7% | -15.1% | -14.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.8% | 7.4% | -3.1% | 1.6% | 3.2% | 6.1% | 8.1% | 1.7% | -1.3% | 1.1%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -30.1% | -14.9% | -10.7% | -20.4% | -16.3% | -23.9% | -6.4% | -12.9% | -9.9% | -6.8%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -58.7% | -40.3% | -24.6% | -28.6% | -14.0% | -45.1% | -37.9% | -20.8% | -13.9% | -12.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.7% | 1.1% | 0.6% | 0.3% | 0.7% | 0.9% | 1.3% | 0.9% | 0.5% | 0.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -13.7% | -6.3% | -4.4% | -2.4% | -1.3% | -12.0% | -5.1% | -3.6% | -1.8% | -0.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -33.8% | -19.1% | -11.8% | -7.5% | -4.9% | -32.5% | -18.1% | -11.0% | -6.6% | -4.2%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -1.0% | -0.6% | 0.0% | -0.9% | 2.7% | 1.0% | 1.5% | 1.4% | 3.0% | 3.4%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -22.5% | -15.3% | -9.8% | -8.8% | -3.9% | -18.6% | -12.4% | -4.8% | -6.3% | -2.4%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -38.1% | -27.6% | -21.8% | -18.2% | -14.3% | -34.1% | -21.8% | -16.8% | -14.9% | -10.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.4% | 4.7% | 1.1% | -2.4% | -2.5% | 3.2% | 6.3% | 4.4% | 0.9% | 2.6%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -26.5% | -15.3% | -15.8% | -14.4% | -10.0% | -21.7% | -13.1% | -11.0% | -8.7% | -5.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -40.0% | -33.3% | -27.1% | -20.4% | -16.6% | -32.2% | -26.0% | -19.8% | -14.2% | -12.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 4.2% | -6.8% | -0.6% | 0.0% | -0.8% | 7.4% | -0.5% | 4.0% | 4.2% | 2.5%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -33.4% | -19.9% | -21.6% | -17.4% | -13.9% | -23.9% | -18.1% | -11.6% | -11.1% | -6.0%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -43.1% | -30.4% | -28.8% | -22.6% | -21.2% | -34.6% | -21.3% | -23.0% | -17.3% | -13.8%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.1% | 0.5% | -0.2% | 0.8% | 0.4% | 0.8% | 1.0% | 0.0% | 1.1% | 0.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -13.8% | -6.5% | -3.7% | -2.3% | -1.4% | -12.2% | -4.8% | -2.4% | -1.3% | -0.7%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -31.2% | -18.8% | -12.1% | -7.5% | -4.0% | -30.1% | -17.4% | -10.7% | -6.4% | -2.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.9% | -0.5% | 0.6% | 0.9% | 0.6% | 1.9% | 1.9% | 2.9% | 2.0% | 1.6%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -21.7% | -15.4% | -9.5% | -6.4% | -5.8% | -16.3% | -11.5% | -6.4% | -4.0% | -2.7%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -38.8% | -27.2% | -20.0% | -16.1% | -12.8% | -34.2% | -22.7% | -15.8% | -12.3% | -9.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -1.5% | -1.6% | 1.7% | 1.3% | 2.4% | 3.4% | 2.2% | 3.8% | 2.3% | 2.9%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -26.3% | -17.1% | -15.8% | -10.4% | -6.9% | -19.7% | -12.2% | -12.3% | -5.9% | -3.7%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -40.3% | -30.3% | -26.0% | -21.2% | -18.1% | -34.7% | -25.4% | -19.4% | -16.0% | -11.8%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -3.7% | 2.6% | 0.9% | 1.5% | 2.7% | 3.5% | 6.5% | 5.5% | 4.9% | 5.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -28.0% | -20.8% | -17.1% | -13.2% | -11.2% | -23.4% | -15.6% | -10.7% | -7.9% | -5.2%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -43.5% | -31.1% | -26.5% | -22.7% | -18.4% | -34.7% | -26.1% | -20.2% | -14.7% | -13.4%

Table E15 Relative bias in the estimated slope, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.6% | -3.3% | -3.4% | -0.6% | -0.8% | 2.6% | -2.9% | -2.6% | 0.6% | 0.0%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -16.3% | -7.2% | -6.5% | 0.4% | -4.0% | -15.7% | -6.3% | -5.6% | 0.0% | -4.3%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -36.0% | -19.8% | -15.2% | -14.3% | -1.8% | -34.4% | -19.7% | -15.2% | -13.8% | -0.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.4% | -8.6% | 3.2% | 4.3% | -9.0% | 3.3% | -8.2% | -1.6% | 9.7% | -3.4%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -31.7% | -14.1% | -8.2% | -9.0% | 0.8% | -25.1% | -14.8% | -12.6% | -1.8% | 4.6%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -63.3% | -26.8% | -27.7% | -14.2% | -13.0% | -58.7% | -24.0% | -19.6% | -5.0% | -5.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 29.0% | 12.9% | 3.6% | -1.3% | 18.2% | 17.1% | 11.8% | 5.8% | 13.2% | 11.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -35.1% | -28.6% | -23.7% | -11.5% | -7.6% | -21.2% | -14.0% | -5.4% | 0.2% | -10.1%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -58.3% | -35.8% | -33.4% | -34.4% | -38.7% | -41.7% | -36.2% | -25.5% | -28.6% | -24.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -13.1% | 37.3% | 3.6% | -46.0% | 0.7% | -11.7% | 35.9% | -17.0% | -3.6% | 15.4%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -22.9% | -13.0% | -42.4% | -22.1% | 13.5% | -7.1% | -17.6% | -50.3% | -9.5% | -6.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -23.6% | -10.9% | -38.9% | -9.8% | -16.6% | -49.8% | -16.0% | -35.9% | -27.5% | 1.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -2.5% | 1.4% | 2.6% | -0.1% | -0.7% | -1.0% | 1.3% | 3.9% | 0.2% | -0.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.9% | -6.7% | -4.0% | -3.0% | -1.9% | -19.4% | -6.2% | -3.3% | -3.8% | -1.7%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -39.9% | -21.1% | -14.8% | -11.7% | -7.7% | -36.1% | -20.0% | -14.9% | -11.4% | -8.3%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.8% | -4.9% | -2.4% | 2.1% | 2.4% | 7.0% | 0.6% | 4.0% | 6.1% | -1.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -15.2% | -16.4% | -14.7% | -13.5% | -4.0% | -10.3% | -6.9% | -9.9% | -5.2% | -1.3%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -48.9% | -41.5% | -24.3% | -19.1% | -15.4% | -45.4% | -34.8% | -19.4% | -17.5% | -10.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -7.7% | 5.3% | -4.8% | 4.8% | -3.1% | -0.3% | 10.9% | 3.0% | 5.6% | 11.0%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -22.0% | -21.1% | -9.2% | -20.1% | -7.6% | -21.8% | -13.4% | -3.2% | -17.0% | -7.9%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -47.5% | -45.6% | -34.7% | -10.9% | -19.0% | -45.2% | -40.6% | -24.9% | -13.2% | -15.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 29.7% | 35.3% | -24.4% | 9.4% | -12.3% | 43.7% | 24.2% | 10.1% | 29.0% | 8.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -23.5% | 2.2% | -21.9% | -15.0% | -1.6% | -10.8% | -2.8% | -5.1% | -18.5% | -13.4%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -38.7% | -46.8% | -45.2% | -27.0% | -19.2% | -36.1% | -38.3% | -26.2% | -29.3% | -8.5%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.0% | -0.6% | -0.4% | -1.1% | 1.1% | 1.6% | 0.8% | 0.8% | -0.4% | 1.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.5% | -6.8% | -5.2% | -3.6% | -3.6% | -12.3% | -6.4% | -4.5% | -3.2% | -2.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -34.0% | -19.7% | -14.5% | -10.3% | -7.3% | -32.4% | -18.3% | -14.2% | -10.1% | -6.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.4% | 5.3% | 0.9% | 0.6% | 2.4% | 3.6% | 10.7% | 5.4% | 4.8% | 6.3%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -21.4% | -14.0% | -13.1% | -6.9% | -4.3% | -16.1% | -13.3% | -10.0% | -4.4% | -2.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -40.8% | -29.5% | -24.7% | -20.9% | -14.7% | -37.1% | -23.9% | -20.6% | -18.5% | -10.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.2% | -1.2% | -7.5% | 0.9% | -1.0% | 8.2% | 7.7% | 6.2% | 6.5% | 3.9%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -22.0% | -24.3% | -17.5% | -19.8% | -9.8% | -16.4% | -14.1% | -12.2% | -14.1% | -5.3%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -38.3% | -28.3% | -28.2% | -23.2% | -25.4% | -37.1% | -19.0% | -24.8% | -18.1% | -17.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -1.8% | 6.0% | -2.2% | 3.6% | 1.4% | 10.2% | 13.3% | 3.4% | 4.1% | 7.4%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -32.7% | -17.6% | -9.9% | -22.4% | -16.3% | -24.8% | -8.8% | -12.8% | -12.7% | -9.2%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -60.9% | -45.9% | -27.9% | -35.5% | -17.7% | -49.0% | -42.4% | -25.4% | -20.8% | -17.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.3% | 1.0% | 0.7% | 0.3% | 0.8% | 1.3% | 2.0% | 1.9% | 1.4% | 1.7%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.1% | -7.2% | -5.5% | -3.5% | -2.1% | -12.7% | -6.2% | -4.5% | -2.9% | -1.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -36.3% | -20.2% | -12.7% | -8.7% | -6.2% | -34.8% | -19.5% | -12.1% | -8.0% | -5.5%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.8% | 0.0% | 0.6% | 0.3% | 3.5% | 3.0% | 4.8% | 4.5% | 7.2% | 7.7%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -22.5% | -15.5% | -10.5% | -9.1% | -4.2% | -18.9% | -13.3% | -6.3% | -6.7% | -2.8%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -41.0% | -31.3% | -24.0% | -20.5% | -15.9% | -36.8% | -25.2% | -19.7% | -17.7% | -12.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.1% | 5.9% | 2.6% | 0.0% | -1.1% | 5.8% | 10.2% | 9.0% | 5.9% | 7.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -27.9% | -17.1% | -17.7% | -15.4% | -10.7% | -23.5% | -15.2% | -13.0% | -9.6% | -6.0%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -43.3% | -37.4% | -30.1% | -23.2% | -19.5% | -36.3% | -30.0% | -23.3% | -17.6% | -16.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 6.5% | -5.7% | -0.2% | 1.0% | 0.5% | 10.5% | 2.7% | 8.1% | 7.9% | 7.0%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -37.3% | -22.1% | -23.4% | -17.7% | -15.1% | -27.6% | -20.2% | -14.4% | -13.1% | -8.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -46.3% | -34.9% | -35.0% | -28.0% | -25.6% | -38.8% | -26.2% | -28.2% | -22.4% | -18.6%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.1% | 0.6% | 0.1% | 1.1% | 0.8% | 1.6% | 1.9% | 1.4% | 2.4% | 2.0%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -13.6% | -6.8% | -4.3% | -2.9% | -1.9% | -12.3% | -5.4% | -2.9% | -1.7% | -0.8%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -33.3% | -19.2% | -12.6% | -7.9% | -4.8% | -32.1% | -18.2% | -11.5% | -7.1% | -3.8%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.0% | 0.3% | 1.8% | 2.5% | 1.9% | 4.3% | 5.0% | 6.8% | 6.4% | 5.9%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -22.7% | -15.4% | -9.9% | -6.5% | -5.6% | -17.6% | -12.2% | -7.0% | -4.7% | -2.9%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -41.4% | -29.7% | -22.5% | -18.1% | -13.9% | -36.8% | -25.3% | -18.6% | -14.9% | -10.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.3% | -0.5% | 2.5% | 2.5% | 3.9% | 6.7% | 5.6% | 7.3% | 6.5% | 8.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -27.9% | -18.1% | -16.3% | -11.0% | -7.4% | -21.1% | -13.8% | -13.6% | -7.2% | -5.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -43.7% | -34.2% | -29.3% | -24.1% | -21.2% | -38.0% | -29.7% | -22.9% | -19.2% | -15.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -3.6% | 3.5% | 2.5% | 3.4% | 4.4% | 6.7% | 9.8% | 9.5% | 9.8% | 10.3%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -29.5% | -22.5% | -18.6% | -14.9% | -12.4% | -25.4% | -16.7% | -12.8% | -10.3% | -6.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -47.4% | -35.9% | -31.5% | -26.5% | -23.5% | -38.8% | -30.9% | -25.3% | -18.8% | -18.6%

Table E16 Mean number of imputed studies, with R studies imputed (from 1-dimensional algorithmic variant)

R Missing Studies Imputed
R Missing Studies Imputed | | | | Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.519 | 0.482 | 0.495 | 0.507 | 0.495
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.757 | 5.040 | 4.978 | 5.035 | 4.970
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 6.601 | 9.086 | 9.834 | 9.970 | 9.889
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.842 | 0.775 | 0.716 | 0.728 | 0.727
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 4.505 | 5.644 | 6.183 | 6.472 | 6.493
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 4.434 | 7.498 | 9.423 | 10.812 | 11.790
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.255 | 1.354 | 1.304 | 1.186 | 1.103
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 4.254 | 5.515 | 6.594 | 7.365 | 7.497
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 3.833 | 6.373 | 8.618 | 10.313 | 11.433
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.673 | 1.868 | 1.968 | 2.151 | 1.904
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 3.959 | 5.484 | 6.872 | 7.507 | 8.167
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 3.259 | 5.792 | 7.908 | 9.676 | 11.325
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.535 | 0.526 | 0.509 | 0.483 | 0.492
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.767 | 4.967 | 4.914 | 5.091 | 5.054
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 6.523 | 8.990 | 9.808 | 9.936 | 9.981
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.854 | 0.816 | 0.819 | 0.726 | 0.752
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 4.605 | 5.648 | 6.172 | 6.525 | 6.703
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 4.519 | 7.411 | 9.662 | 10.660 | 11.961
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.244 | 1.239 | 1.327 | 1.220 | 1.184
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 4.132 | 5.774 | 6.778 | 7.384 | 7.562
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 3.806 | 6.543 | 8.605 | 10.105 | 11.595
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.706 | 1.741 | 1.984 | 2.121 | 1.996
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 3.742 | 5.395 | 6.547 | 7.287 | 8.205
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 3.251 | 5.764 | 7.795 | 9.723 | 11.476
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.502 | 0.515 | 0.499 | 0.513 | 0.470
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.784 | 4.980 | 5.050 | 5.052 | 5.128
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 6.348 | 9.138 | 9.890 | 10.115 | 10.087
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.867 | 0.799 | 0.767 | 0.768 | 0.706
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 4.602 | 5.729 | 6.125 | 6.701 | 6.782
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 4.449 | 7.292 | 9.474 | 10.669 | 11.622
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.241 | 1.284 | 1.283 | 1.222 | 1.251
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 4.293 | 5.704 | 6.549 | 7.462 | 7.657
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 3.768 | 6.600 | 8.515 | 10.168 | 11.104
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.754 | 1.813 | 1.972 | 2.054 | 1.932
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 3.831 | 5.629 | 6.800 | 7.636 | 8.604
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 3.279 | 5.735 | 7.977 | 10.009 | 11.235
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.533 | 0.518 | 0.544 | 0.536 | 0.490
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.910 | 5.285 | 5.325 | 5.273 | 5.263
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 5.739 | 8.776 | 9.994 | 10.488 | 10.821
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.888 | 0.882 | 0.798 | 0.732 | 0.815
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 4.459 | 5.773 | 6.473 | 6.788 | 6.711
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 4.413 | 7.377 | 9.255 | 10.805 | 11.819
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.299 | 1.287 | 1.364 | 1.267 | 1.270
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 3.953 | 5.580 | 6.728 | 7.727 | 7.630
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 3.677 | 6.473 | 8.636 | 10.102 | 11.443
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.572 | 1.839 | 1.915 | 2.012 | 1.843
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 3.844 | 5.444 | 6.418 | 7.567 | 8.045
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 3.255 | 5.792 | 7.779 | 9.780 | 10.936
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.645 | 0.584 | 0.569 | 0.558 | 0.564
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.901 | 5.786 | 5.781 | 5.718 | 5.526
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 5.195 | 8.306 | 10.135 | 11.031 | 11.451
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.951 | 0.898 | 0.812 | 0.843 | 0.793
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 4.406 | 5.872 | 6.624 | 6.747 | 6.987
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 4.291 | 7.216 | 9.159 | 10.447 | 11.744
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.289 | 1.319 | 1.366 | 1.315 | 1.307
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 4.147 | 5.866 | 6.828 | 7.378 | 7.669
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 3.771 | 6.185 | 8.549 | 10.194 | 11.627
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.664 | 1.917 | 1.981 | 1.897 | 1.907
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 3.902 | 5.459 | 6.454 | 7.599 | 8.270
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 3.195 | 5.697 | 8.039 | 9.745 | 11.002

Table E17 Mean number of imputed studies, with L studies imputed (from 1-dimensional algorithmic variant)

L Missing Studies Imputed
L Missing Studies Imputed | | | | Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.211 | 1.342 | 1.616 | 1.774 | 1.884
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.887 | 4.485 | 4.701 | 5.061 | 5.135
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.668 | 6.606 | 7.602 | 8.197 | 8.501
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.900 | 2.385 | 2.771 | 3.178 | 3.641
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.319 | 4.376 | 5.194 | 5.941 | 6.637
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.080 | 4.762 | 6.100 | 7.283 | 8.287
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.325 | 3.075 | 3.653 | 4.308 | 4.803
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 3.025 | 4.025 | 5.050 | 6.141 | 6.883
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.531 | 3.915 | 5.115 | 6.319 | 7.278
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.692 | 3.610 | 4.531 | 5.635 | 6.247
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.705 | 3.744 | 4.822 | 5.881 | 7.020
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.086 | 3.259 | 4.429 | 5.556 | 6.692
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.222 | 1.436 | 1.573 | 1.774 | 1.917
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.894 | 4.421 | 4.652 | 5.016 | 5.237
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.574 | 6.507 | 7.535 | 8.194 | 8.635
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.902 | 2.361 | 2.890 | 3.164 | 3.634
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.394 | 4.336 | 5.101 | 6.002 | 6.607
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.107 | 4.743 | 6.238 | 7.238 | 8.368
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.304 | 2.929 | 3.694 | 4.279 | 5.013
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.942 | 4.116 | 5.113 | 6.062 | 6.929
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.497 | 3.882 | 5.188 | 6.113 | 7.454
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.765 | 3.547 | 4.810 | 5.594 | 6.303
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.609 | 3.779 | 4.877 | 5.768 | 6.831
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.058 | 3.252 | 4.335 | 5.576 | 6.794
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.240 | 1.453 | 1.685 | 1.829 | 1.971
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.905 | 4.350 | 4.791 | 5.023 | 5.237
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.503 | 6.508 | 7.453 | 8.177 | 8.579
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.791 | 2.296 | 2.772 | 3.168 | 3.586
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.364 | 4.398 | 5.155 | 6.069 | 6.674
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.042 | 4.661 | 6.104 | 7.187 | 8.215
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.296 | 3.028 | 3.696 | 4.470 | 4.957
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 3.005 | 4.066 | 5.024 | 6.214 | 6.872
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.455 | 3.921 | 5.052 | 6.242 | 7.189
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.696 | 3.682 | 4.738 | 5.638 | 6.349
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.631 | 3.822 | 4.966 | 5.951 | 7.098
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.063 | 3.169 | 4.459 | 5.744 | 6.687
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.331 | 1.573 | 1.890 | 2.151 | 2.266
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.821 | 4.548 | 4.983 | 5.272 | 5.505
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.043 | 6.053 | 7.289 | 8.112 | 8.757
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.933 | 2.353 | 2.867 | 3.470 | 3.829
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.289 | 4.409 | 5.377 | 6.143 | 6.604
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.009 | 4.691 | 5.935 | 7.179 | 8.116
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.337 | 2.971 | 3.853 | 4.406 | 5.202
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.796 | 4.053 | 5.081 | 6.207 | 6.760
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.442 | 3.865 | 5.143 | 6.128 | 7.343
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.694 | 3.645 | 4.594 | 5.369 | 6.221
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.589 | 3.717 | 4.741 | 5.809 | 6.826
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.050 | 3.325 | 4.337 | 5.648 | 6.576
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.526 | 1.769 | 2.109 | 2.400 | 2.750
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.740 | 4.669 | 5.193 | 5.670 | 5.955
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 3.652 | 5.575 | 7.001 | 7.970 | 8.786
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 2.000 | 2.541 | 2.905 | 3.509 | 3.948
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.235 | 4.474 | 5.294 | 5.959 | 6.831
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.950 | 4.491 | 5.733 | 6.929 | 8.089
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.367 | 3.063 | 3.826 | 4.429 | 5.244
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.877 | 4.214 | 5.122 | 6.150 | 6.873
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.491 | 3.646 | 5.107 | 6.210 | 7.348
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.688 | 3.824 | 4.613 | 5.460 | 6.304
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.651 | 3.755 | 4.788 | 5.912 | 6.986
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.030 | 3.201 | 4.416 | 5.655 | 6.477

Table E18 Absolute bias in the estimated intercept, with no correction for publication bias (from 2-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | 0.001 | 0.000 | 0.001 | 0.000 | 0.000 | 0.001 | 0.000 | 0.001 | 0.000
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.041 | 0.026 | 0.019 | 0.014 | 0.010 | 0.043 | 0.027 | 0.020 | 0.015 | 0.011
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.111 | 0.062 | 0.040 | 0.030 | 0.024 | 0.115 | 0.064 | 0.042 | 0.031 | 0.025
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.002 | 0.003 | -0.001 | 0.001 | 0.000 | 0.003 | 0.001 | -0.002 | 0.002 | -0.001
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.081 | 0.050 | 0.037 | 0.027 | 0.018 | 0.099 | 0.067 | 0.054 | 0.045 | 0.035
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.188 | 0.119 | 0.084 | 0.069 | 0.052 | 0.198 | 0.136 | 0.104 | 0.089 | 0.073
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.001 | -0.007 | -0.004 | 0.001 | 0.002 | 0.002 | 0.000 | -0.001 | -0.002 | 0.000
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.135 | 0.082 | 0.066 | 0.047 | 0.042 | 0.154 | 0.112 | 0.091 | 0.074 | 0.066
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.271 | 0.180 | 0.143 | 0.118 | 0.089 | 0.292 | 0.209 | 0.171 | 0.146 | 0.123
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.001 | -0.018 | -0.005 | 0.001 | 0.007 | 0.002 | -0.006 | -0.001 | -0.001 | -0.001
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.213 | 0.167 | 0.130 | 0.107 | 0.092 | 0.244 | 0.190 | 0.154 | 0.132 | 0.111
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.450 | 0.319 | 0.251 | 0.209 | 0.174 | 0.467 | 0.352 | 0.277 | 0.235 | 0.201
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | -0.001 | 0.001 | 0.001 | 0.001 | -0.003 | -0.001 | 0.001 | 0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.043 | 0.026 | 0.019 | 0.014 | 0.012 | 0.046 | 0.028 | 0.020 | 0.015 | 0.013
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.123 | 0.065 | 0.043 | 0.032 | 0.025 | 0.127 | 0.068 | 0.045 | 0.033 | 0.026
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.005 | 0.003 | -0.001 | 0.000 | 0.001 | 0.003 | 0.003 | -0.002 | 0.002 | 0.000
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.080 | 0.057 | 0.037 | 0.028 | 0.023 | 0.099 | 0.076 | 0.057 | 0.046 | 0.039
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.196 | 0.127 | 0.088 | 0.070 | 0.054 | 0.207 | 0.142 | 0.109 | 0.091 | 0.079
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.002 | -0.001 | -0.006 | 0.002 | 0.000 | 0.001 | 0.002 | -0.002 | -0.001 | 0.000
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.129 | 0.091 | 0.071 | 0.058 | 0.039 | 0.156 | 0.113 | 0.098 | 0.080 | 0.065
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.287 | 0.197 | 0.145 | 0.127 | 0.103 | 0.304 | 0.218 | 0.177 | 0.150 | 0.127
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.008 | -0.010 | 0.007 | 0.003 | 0.003 | -0.001 | -0.004 | 0.008 | 0.005 | 0.001
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.223 | 0.165 | 0.128 | 0.116 | 0.099 | 0.250 | 0.195 | 0.155 | 0.133 | 0.115
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.450 | 0.320 | 0.261 | 0.206 | 0.181 | 0.475 | 0.347 | 0.287 | 0.238 | 0.207
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.001 | 0.001 | -0.001 | -0.001 | 0.001 | 0.001 | 0.001 | -0.001 | -0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.050 | 0.030 | 0.022 | 0.016 | 0.013 | 0.054 | 0.032 | 0.023 | 0.017 | 0.014
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.144 | 0.076 | 0.051 | 0.036 | 0.028 | 0.148 | 0.079 | 0.052 | 0.038 | 0.029
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.004 | -0.002 | -0.001 | 0.002 | 0.001 | -0.001 | 0.001 | 0.003 | 0.000 | 0.002
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.090 | 0.064 | 0.040 | 0.032 | 0.025 | 0.110 | 0.082 | 0.061 | 0.051 | 0.044
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.217 | 0.140 | 0.101 | 0.077 | 0.066 | 0.229 | 0.158 | 0.122 | 0.102 | 0.090
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.002 | 0.002 | 0.000 | 0.001 | -0.001 | -0.007 | 0.001 | -0.001 | 0.001 | 0.000
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.150 | 0.100 | 0.077 | 0.062 | 0.054 | 0.173 | 0.129 | 0.102 | 0.088 | 0.076
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.304 | 0.217 | 0.163 | 0.134 | 0.108 | 0.324 | 0.238 | 0.190 | 0.161 | 0.139
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.011 | -0.005 | -0.006 | 0.004 | 0.004 | -0.003 | 0.001 | 0.000 | -0.002 | 0.002
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.255 | 0.182 | 0.145 | 0.111 | 0.096 | 0.274 | 0.203 | 0.170 | 0.144 | 0.120
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.476 | 0.338 | 0.264 | 0.224 | 0.196 | 0.495 | 0.364 | 0.298 | 0.252 | 0.224
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | 0.001 | -0.001 | -0.001 | 0.001 | 0.000 | 0.001 | -0.002 | -0.001 | 0.001
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.067 | 0.040 | 0.027 | 0.020 | 0.016 | 0.071 | 0.042 | 0.029 | 0.021 | 0.017
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.187 | 0.099 | 0.066 | 0.047 | 0.037 | 0.191 | 0.102 | 0.068 | 0.049 | 0.038
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | -0.001 | 0.000 | -0.002 | -0.001 | -0.001 | 0.002 | 0.000 | -0.001 | 0.000
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.114 | 0.078 | 0.054 | 0.038 | 0.032 | 0.137 | 0.098 | 0.076 | 0.063 | 0.055
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.261 | 0.175 | 0.128 | 0.102 | 0.080 | 0.273 | 0.192 | 0.150 | 0.126 | 0.107
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.006 | 0.004 | 0.002 | 0.001 | -0.002 | -0.002 | 0.001 | 0.002 | -0.001 | -0.001
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.177 | 0.122 | 0.087 | 0.072 | 0.061 | 0.199 | 0.151 | 0.115 | 0.105 | 0.087
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.337 | 0.243 | 0.192 | 0.152 | 0.129 | 0.359 | 0.270 | 0.220 | 0.185 | 0.162
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.008 | -0.012 | 0.003 | -0.006 | -0.007 | 0.002 | -0.003 | 0.001 | 0.000 | -0.003
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.276 | 0.206 | 0.163 | 0.139 | 0.115 | 0.300 | 0.230 | 0.187 | 0.158 | 0.142
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.512 | 0.377 | 0.299 | 0.252 | 0.212 | 0.534 | 0.405 | 0.327 | 0.283 | 0.241
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | 0.000 | 0.001 | 0.000 | 0.000 | 0.001 | 0.000 | 0.001 | 0.000 | -0.001
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.078 | 0.046 | 0.031 | 0.025 | 0.019 | 0.083 | 0.049 | 0.033 | 0.027 | 0.020
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.221 | 0.120 | 0.078 | 0.059 | 0.044 | 0.226 | 0.124 | 0.081 | 0.060 | 0.046
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.002 | 0.001 | 0.001 | 0.001 | -0.001 | 0.000 | 0.002 | 0.002 | 0.001 | -0.002
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.138 | 0.092 | 0.061 | 0.050 | 0.036 | 0.159 | 0.114 | 0.088 | 0.074 | 0.060
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.299 | 0.202 | 0.148 | 0.114 | 0.094 | 0.313 | 0.223 | 0.175 | 0.143 | 0.123
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.006 | -0.006 | -0.003 | -0.001 | -0.001 | -0.004 | -0.003 | 0.001 | 0.002 | 0.004
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.191 | 0.147 | 0.110 | 0.089 | 0.068 | 0.221 | 0.173 | 0.140 | 0.119 | 0.100
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.388 | 0.283 | 0.219 | 0.171 | 0.156 | 0.410 | 0.307 | 0.250 | 0.208 | 0.186
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.003 | -0.002 | -0.008 | -0.009 | -0.004 | 0.004 | 0.002 | 0.000 | 0.002 | -0.002
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.295 | 0.234 | 0.176 | 0.152 | 0.125 | 0.321 | 0.258 | 0.206 | 0.173 | 0.152
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.559 | 0.404 | 0.336 | 0.282 | 0.244 | 0.583 | 0.439 | 0.361 | 0.308 | 0.272

Table E19 Absolute bias in the estimated intercept, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.001 | -0.002 | 0.000 | -0.001 | -0.004 | -0.002 | -0.002 | 0.000 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.015 | 0.006 | 0.004 | 0.003 | 0.000 | 0.016 | 0.007 | 0.004 | 0.003 | 0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.069 | 0.026 | 0.012 | 0.006 | 0.005 | 0.071 | 0.027 | 0.013 | 0.007 | 0.005
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.005 | -0.001 | -0.005 | -0.001 | -0.002 | -0.010 | -0.008 | -0.009 | -0.004 | -0.006
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.046 | 0.018 | 0.013 | 0.005 | 0.000 | 0.047 | 0.015 | 0.010 | 0.004 | 0.000
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.149 | 0.078 | 0.046 | 0.033 | 0.019 | 0.148 | 0.078 | 0.045 | 0.031 | 0.016
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.013 | -0.017 | -0.011 | -0.005 | -0.003 | -0.025 | -0.023 | -0.018 | -0.016 | -0.011
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.093 | 0.038 | 0.029 | 0.013 | 0.012 | 0.082 | 0.034 | 0.020 | 0.007 | 0.005
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.228 | 0.128 | 0.092 | 0.069 | 0.042 | 0.228 | 0.124 | 0.086 | 0.061 | 0.039
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.031 | -0.039 | -0.023 | -0.014 | -0.006 | -0.058 | -0.053 | -0.040 | -0.034 | -0.029
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.154 | 0.102 | 0.068 | 0.048 | 0.036 | 0.136 | 0.075 | 0.043 | 0.023 | 0.009
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.391 | 0.249 | 0.179 | 0.134 | 0.101 | 0.364 | 0.228 | 0.152 | 0.109 | 0.073
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.002 | -0.004 | -0.002 | -0.001 | 0.000 | -0.003 | -0.005 | -0.003 | -0.001 | 0.000
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.015 | 0.007 | 0.004 | 0.002 | 0.003 | 0.016 | 0.008 | 0.004 | 0.002 | 0.003
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.077 | 0.028 | 0.015 | 0.008 | 0.005 | 0.078 | 0.029 | 0.016 | 0.009 | 0.006
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | -0.002 | -0.004 | -0.002 | -0.001 | -0.009 | -0.006 | -0.009 | -0.004 | -0.004
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.045 | 0.026 | 0.012 | 0.006 | 0.004 | 0.047 | 0.025 | 0.011 | 0.004 | 0.003
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.152 | 0.085 | 0.047 | 0.033 | 0.021 | 0.153 | 0.085 | 0.047 | 0.031 | 0.021
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.017 | -0.012 | -0.013 | -0.004 | -0.004 | -0.030 | -0.021 | -0.018 | -0.014 | -0.011
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.088 | 0.045 | 0.031 | 0.023 | 0.006 | 0.084 | 0.035 | 0.026 | 0.014 | 0.002
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.240 | 0.144 | 0.092 | 0.073 | 0.053 | 0.235 | 0.133 | 0.089 | 0.059 | 0.042
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.032 | -0.032 | -0.012 | -0.012 | -0.010 | -0.057 | -0.051 | -0.031 | -0.028 | -0.026
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.159 | 0.100 | 0.066 | 0.062 | 0.044 | 0.132 | 0.078 | 0.044 | 0.029 | 0.015
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.396 | 0.249 | 0.187 | 0.130 | 0.109 | 0.382 | 0.222 | 0.156 | 0.109 | 0.084
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.002 | -0.001 | -0.001 | -0.002 | -0.001 | -0.003 | -0.002 | -0.001 | -0.002 | -0.002
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.023 | 0.010 | 0.007 | 0.004 | 0.004 | 0.025 | 0.011 | 0.007 | 0.005 | 0.004
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.091 | 0.037 | 0.020 | 0.013 | 0.009 | 0.092 | 0.038 | 0.021 | 0.014 | 0.010
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.010 | -0.006 | -0.004 | 0.000 | 0.000 | -0.014 | -0.008 | -0.004 | -0.005 | -0.002
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.052 | 0.030 | 0.013 | 0.010 | 0.006 | 0.052 | 0.027 | 0.015 | 0.009 | 0.007
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.168 | 0.091 | 0.057 | 0.037 | 0.031 | 0.170 | 0.089 | 0.055 | 0.037 | 0.030
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.016 | -0.007 | -0.007 | -0.004 | -0.005 | -0.035 | -0.020 | -0.019 | -0.012 | -0.012
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.103 | 0.055 | 0.038 | 0.026 | 0.021 | 0.095 | 0.048 | 0.030 | 0.017 | 0.014
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.256 | 0.162 | 0.105 | 0.080 | 0.056 | 0.251 | 0.147 | 0.094 | 0.069 | 0.048
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.039 | -0.026 | -0.025 | -0.012 | -0.009 | -0.062 | -0.046 | -0.038 | -0.035 | -0.026
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.193 | 0.115 | 0.082 | 0.048 | 0.040 | 0.161 | 0.082 | 0.056 | 0.032 | 0.016
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.413 | 0.263 | 0.186 | 0.145 | 0.119 | 0.387 | 0.237 | 0.162 | 0.120 | 0.090
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.001 | -0.003 | -0.002 | 0.000 | -0.003 | -0.001 | -0.003 | -0.003 | 0.000
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.035 | 0.019 | 0.014 | 0.010 | 0.008 | 0.036 | 0.021 | 0.016 | 0.011 | 0.009
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.116 | 0.052 | 0.034 | 0.024 | 0.019 | 0.116 | 0.053 | 0.036 | 0.026 | 0.021
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.007 | -0.006 | -0.003 | -0.004 | -0.003 | -0.012 | -0.008 | -0.007 | -0.007 | -0.005
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.073 | 0.043 | 0.027 | 0.017 | 0.014 | 0.074 | 0.042 | 0.028 | 0.024 | 0.019
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.199 | 0.117 | 0.077 | 0.059 | 0.044 | 0.196 | 0.113 | 0.074 | 0.057 | 0.045
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.021 | -0.007 | -0.006 | -0.004 | -0.007 | -0.032 | -0.022 | -0.016 | -0.015 | -0.012
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.124 | 0.073 | 0.042 | 0.036 | 0.028 | 0.111 | 0.066 | 0.037 | 0.036 | 0.024
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.274 | 0.174 | 0.128 | 0.091 | 0.072 | 0.267 | 0.164 | 0.114 | 0.082 | 0.065
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.021 | -0.035 | -0.015 | -0.022 | -0.020 | -0.052 | -0.053 | -0.037 | -0.031 | -0.032
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.198 | 0.135 | 0.093 | 0.070 | 0.056 | 0.171 | 0.103 | 0.066 | 0.039 | 0.037
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.440 | 0.291 | 0.209 | 0.161 | 0.129 | 0.413 | 0.263 | 0.180 | 0.133 | 0.098
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.002 | -0.001 | -0.002 | -0.001 | -0.003 | -0.003 | -0.001 | -0.002 | -0.002
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.046 | 0.027 | 0.018 | 0.015 | 0.011 | 0.049 | 0.029 | 0.020 | 0.017 | 0.013
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.135 | 0.071 | 0.048 | 0.038 | 0.028 | 0.135 | 0.073 | 0.051 | 0.040 | 0.031
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.008 | -0.003 | -0.002 | -0.001 | -0.002 | -0.013 | -0.006 | -0.005 | -0.005 | -0.007
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.090 | 0.056 | 0.034 | 0.029 | 0.019 | 0.090 | 0.056 | 0.039 | 0.034 | 0.026
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.225 | 0.137 | 0.096 | 0.069 | 0.057 | 0.221 | 0.134 | 0.097 | 0.071 | 0.061
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.019 | -0.015 | -0.010 | -0.006 | -0.005 | -0.032 | -0.024 | -0.017 | -0.012 | -0.008
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.132 | 0.095 | 0.063 | 0.050 | 0.034 | 0.126 | 0.084 | 0.057 | 0.043 | 0.033
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.316 | 0.206 | 0.148 | 0.107 | 0.097 | 0.306 | 0.189 | 0.133 | 0.101 | 0.087
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.023 | -0.027 | -0.029 | -0.025 | -0.015 | -0.051 | -0.047 | -0.042 | -0.032 | -0.029
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.220 | 0.157 | 0.106 | 0.088 | 0.062 | 0.190 | 0.126 | 0.080 | 0.059 | 0.040
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.475 | 0.308 | 0.241 | 0.191 | 0.152 | 0.447 | 0.282 | 0.202 | 0.153 | 0.122

Table E20 Absolute bias in the estimated intercept, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.007 | -0.004 | -0.005 | -0.003 | -0.004 | -0.008 | -0.005 | -0.006 | -0.003 | -0.004
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.019 | 0.008 | 0.005 | 0.002 | 0.000 | 0.021 | 0.010 | 0.006 | 0.003 | 0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.076 | 0.033 | 0.016 | 0.010 | 0.007 | 0.078 | 0.035 | 0.018 | 0.011 | 0.008
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.013 | -0.011 | -0.014 | -0.011 | -0.011 | -0.026 | -0.024 | -0.028 | -0.022 | -0.024
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.051 | 0.020 | 0.013 | 0.003 | -0.003 | 0.054 | 0.019 | 0.011 | 0.002 | -0.004
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.156 | 0.087 | 0.054 | 0.038 | 0.024 | 0.157 | 0.090 | 0.056 | 0.040 | 0.024
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.029 | -0.035 | -0.034 | -0.024 | -0.025 | -0.055 | -0.056 | -0.058 | -0.050 | -0.053
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.096 | 0.043 | 0.030 | 0.009 | 0.006 | 0.088 | 0.040 | 0.022 | 0.003 | -0.003
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.236 | 0.140 | 0.103 | 0.080 | 0.051 | 0.238 | 0.142 | 0.102 | 0.076 | 0.052
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.054 | -0.074 | -0.063 | -0.056 | -0.047 | -0.101 | -0.111 | -0.107 | -0.104 | -0.098
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.160 | 0.110 | 0.072 | 0.047 | 0.030 | 0.146 | 0.085 | 0.047 | 0.023 | -0.001
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.402 | 0.269 | 0.199 | 0.155 | 0.118 | 0.381 | 0.255 | 0.179 | 0.136 | 0.095
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.006 | -0.008 | -0.006 | -0.003 | -0.003 | -0.007 | -0.009 | -0.006 | -0.004 | -0.003
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.018 | 0.009 | 0.004 | 0.002 | 0.003 | 0.020 | 0.010 | 0.005 | 0.003 | 0.003
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.083 | 0.035 | 0.020 | 0.012 | 0.008 | 0.085 | 0.036 | 0.022 | 0.013 | 0.009
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.010 | -0.010 | -0.013 | -0.011 | -0.011 | -0.024 | -0.022 | -0.026 | -0.022 | -0.023
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.049 | 0.027 | 0.012 | 0.004 | 0.000 | 0.054 | 0.028 | 0.011 | 0.003 | -0.002
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.161 | 0.094 | 0.056 | 0.039 | 0.025 | 0.164 | 0.097 | 0.060 | 0.041 | 0.027
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.032 | -0.030 | -0.032 | -0.023 | -0.026 | -0.057 | -0.054 | -0.054 | -0.051 | -0.050
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.090 | 0.050 | 0.031 | 0.020 | 0.000 | 0.089 | 0.042 | 0.025 | 0.011 | -0.006
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.248 | 0.157 | 0.104 | 0.085 | 0.062 | 0.246 | 0.151 | 0.106 | 0.074 | 0.054
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.061 | -0.067 | -0.048 | -0.051 | -0.052 | -0.105 | -0.109 | -0.092 | -0.095 | -0.093
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.165 | 0.107 | 0.072 | 0.060 | 0.040 | 0.141 | 0.086 | 0.051 | 0.027 | 0.008
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.407 | 0.269 | 0.205 | 0.150 | 0.125 | 0.398 | 0.252 | 0.182 | 0.134 | 0.107
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.006 | -0.005 | -0.004 | -0.005 | -0.004 | -0.007 | -0.006 | -0.004 | -0.006 | -0.005
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.026 | 0.011 | 0.007 | 0.004 | 0.003 | 0.029 | 0.013 | 0.008 | 0.005 | 0.004
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.097 | 0.043 | 0.024 | 0.016 | 0.011 | 0.099 | 0.045 | 0.026 | 0.017 | 0.012
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.020 | -0.015 | -0.013 | -0.009 | -0.010 | -0.030 | -0.025 | -0.022 | -0.024 | -0.022
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.055 | 0.033 | 0.013 | 0.008 | 0.003 | 0.058 | 0.032 | 0.015 | 0.007 | 0.001
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.175 | 0.101 | 0.065 | 0.043 | 0.034 | 0.178 | 0.102 | 0.067 | 0.046 | 0.036
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.031 | -0.026 | -0.026 | -0.024 | -0.026 | -0.061 | -0.052 | -0.054 | -0.048 | -0.049
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.107 | 0.060 | 0.037 | 0.025 | 0.016 | 0.100 | 0.056 | 0.030 | 0.016 | 0.006
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.265 | 0.175 | 0.118 | 0.090 | 0.064 | 0.264 | 0.166 | 0.112 | 0.084 | 0.060
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.070 | -0.060 | -0.062 | -0.053 | -0.050 | -0.112 | -0.103 | -0.102 | -0.104 | -0.095
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.200 | 0.123 | 0.088 | 0.046 | 0.034 | 0.171 | 0.090 | 0.061 | 0.028 | 0.009
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.427 | 0.281 | 0.206 | 0.162 | 0.136 | 0.406 | 0.260 | 0.190 | 0.141 | 0.113
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.007 | -0.004 | -0.006 | -0.005 | -0.003 | -0.008 | -0.005 | -0.007 | -0.006 | -0.003
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.038 | 0.020 | 0.013 | 0.008 | 0.006 | 0.040 | 0.023 | 0.015 | 0.009 | 0.007
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.124 | 0.058 | 0.037 | 0.024 | 0.018 | 0.124 | 0.060 | 0.039 | 0.027 | 0.021
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.017 | -0.015 | -0.013 | -0.014 | -0.013 | -0.030 | -0.024 | -0.026 | -0.026 | -0.024
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.077 | 0.045 | 0.025 | 0.014 | 0.009 | 0.080 | 0.044 | 0.025 | 0.018 | 0.011
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.209 | 0.127 | 0.085 | 0.064 | 0.047 | 0.207 | 0.125 | 0.085 | 0.064 | 0.050
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.037 | -0.026 | -0.026 | -0.027 | -0.028 | -0.061 | -0.056 | -0.051 | -0.053 | -0.050
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.130 | 0.076 | 0.043 | 0.032 | 0.021 | 0.120 | 0.071 | 0.037 | 0.030 | 0.014
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.285 | 0.191 | 0.141 | 0.103 | 0.081 | 0.282 | 0.185 | 0.132 | 0.099 | 0.077
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.054 | -0.070 | -0.057 | -0.067 | -0.063 | -0.109 | -0.106 | -0.101 | -0.103 | -0.104
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.209 | 0.142 | 0.094 | 0.074 | 0.051 | 0.184 | 0.112 | 0.068 | 0.042 | 0.028
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.455 | 0.312 | 0.233 | 0.182 | 0.146 | 0.432 | 0.291 | 0.210 | 0.160 | 0.121
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.007 | -0.006 | -0.004 | -0.004 | -0.004 | -0.009 | -0.007 | -0.005 | -0.005 | -0.005
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 0.046 | 0.025 | 0.016 | 0.013 | 0.009 | 0.049 | 0.027 | 0.017 | 0.014 | 0.011
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 0.141 | 0.074 | 0.047 | 0.035 | 0.024 | 0.142 | 0.076 | 0.050 | 0.037 | 0.027
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.017 | -0.014 | -0.012 | -0.010 | -0.012 | -0.028 | -0.025 | -0.024 | -0.023 | -0.025
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 0.094 | 0.056 | 0.030 | 0.024 | 0.013 | 0.094 | 0.056 | 0.034 | 0.027 | 0.015
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 0.234 | 0.146 | 0.102 | 0.072 | 0.058 | 0.231 | 0.145 | 0.104 | 0.075 | 0.061
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.036 | -0.033 | -0.030 | -0.027 | -0.028 | -0.062 | -0.057 | -0.052 | -0.048 | -0.048
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 0.136 | 0.097 | 0.062 | 0.044 | 0.025 | 0.131 | 0.087 | 0.054 | 0.035 | 0.020
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 0.327 | 0.223 | 0.161 | 0.118 | 0.105 | 0.320 | 0.209 | 0.151 | 0.115 | 0.097
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.051 | -0.062 | -0.068 | -0.070 | -0.057 | -0.097 | -0.104 | -0.108 | -0.104 | -0.100
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.226 | 0.162 | 0.108 | 0.085 | 0.054 | 0.197 | 0.131 | 0.082 | 0.056 | 0.028
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 0.492 | 0.331 | 0.264 | 0.210 | 0.167 | 0.469 | 0.311 | 0.232 | 0.179 | 0.142

Table E21 Coverage probability of the estimated intercept, with no correction for publication bias (from 2-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.8% | 95.2% | 95.1% | 95.0% | 94.8% | 96.1% | 96.3% | 96.3% | 96.2% | 95.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.9% | 94.3% | 94.2% | 94.2% | 94.9% | 94.2% | 94.6% | 94.6% | 94.4% | 95.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.8% | 89.9% | 91.8% | 92.7% | 92.6% | 87.9% | 90.0% | 91.9% | 92.9% | 92.8%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.7% | 61.6% | 56.4% | 53.9% | 51.8% | 91.7% | 93.2% | 93.1% | 93.2% | 93.8%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 64.5% | 60.6% | 56.6% | 54.7% | 54.9% | 81.9% | 86.1% | 88.3% | 89.3% | 91.2%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 58.8% | 56.2% | 55.3% | 53.4% | 52.9% | 65.7% | 69.5% | 75.4% | 77.2% | 81.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.0% | 40.1% | 39.7% | 37.3% | 35.3% | 93.0% | 92.9% | 93.7% | 93.9% | 94.2%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 48.5% | 44.6% | 39.5% | 38.5% | 35.6% | 81.8% | 86.3% | 87.6% | 89.6% | 90.1%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 41.9% | 39.8% | 38.8% | 36.6% | 35.8% | 59.4% | 67.3% | 73.0% | 75.4% | 78.8%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.1% | 25.4% | 24.0% | 21.1% | 21.5% | 92.1% | 93.3% | 93.2% | 93.6% | 94.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 32.1% | 27.8% | 26.4% | 23.8% | 23.8% | 82.0% | 85.0% | 86.7% | 87.7% | 88.6%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.5% | 24.9% | 24.7% | 23.1% | 22.6% | 56.5% | 64.0% | 69.5% | 74.0% | 76.4%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.6% | 95.1% | 95.2% | 94.2% | 95.1% | 96.0% | 96.1% | 96.5% | 95.5% | 96.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.7% | 94.5% | 94.1% | 94.0% | 94.7% | 94.0% | 94.9% | 94.4% | 94.5% | 94.9%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 84.9% | 89.1% | 90.3% | 92.0% | 92.8% | 85.5% | 89.2% | 90.3% | 92.0% | 92.9%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.3% | 59.6% | 55.9% | 54.2% | 54.1% | 92.2% | 93.3% | 93.4% | 94.3% | 94.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 64.3% | 59.6% | 58.3% | 54.0% | 53.9% | 81.8% | 84.9% | 87.0% | 88.7% | 90.9%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 57.4% | 55.3% | 55.2% | 53.5% | 52.7% | 64.9% | 68.2% | 74.6% | 78.2% | 80.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.3% | 40.4% | 38.2% | 36.7% | 36.3% | 92.3% | 93.0% | 93.8% | 94.3% | 93.9%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 48.6% | 43.5% | 39.6% | 38.4% | 37.2% | 82.2% | 85.3% | 87.7% | 88.5% | 90.7%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 40.0% | 39.6% | 38.9% | 35.3% | 34.9% | 57.8% | 66.5% | 71.5% | 74.7% | 78.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 29.4% | 24.3% | 23.1% | 23.0% | 21.2% | 93.0% | 92.9% | 93.1% | 93.2% | 94.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 31.4% | 27.9% | 26.2% | 23.2% | 21.5% | 80.2% | 84.1% | 85.6% | 86.9% | 88.4%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.7% | 25.6% | 24.1% | 22.8% | 21.7% | 55.6% | 64.2% | 69.0% | 72.2% | 74.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.7% | 95.5% | 95.0% | 94.9% | 94.9% | 96.2% | 96.5% | 96.2% | 96.2% | 95.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.5% | 93.6% | 94.1% | 94.6% | 94.3% | 92.9% | 93.9% | 94.3% | 94.8% | 94.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 82.0% | 86.0% | 88.7% | 90.8% | 92.3% | 82.4% | 86.2% | 88.9% | 90.7% | 92.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.8% | 59.0% | 57.3% | 55.1% | 52.2% | 91.8% | 92.7% | 92.7% | 93.8% | 94.3%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.9% | 59.1% | 57.8% | 54.1% | 53.8% | 81.4% | 84.1% | 86.5% | 88.5% | 90.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 53.5% | 53.1% | 52.6% | 52.3% | 50.2% | 60.6% | 65.6% | 71.3% | 75.4% | 78.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.2% | 41.7% | 40.1% | 37.5% | 35.3% | 92.3% | 93.5% | 93.7% | 94.1% | 93.6%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 47.4% | 42.1% | 39.3% | 37.4% | 36.8% | 80.1% | 83.9% | 86.0% | 87.6% | 88.8%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 37.9% | 37.4% | 35.8% | 35.4% | 35.0% | 53.7% | 63.6% | 69.1% | 73.1% | 75.6%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.1% | 26.6% | 22.8% | 23.5% | 22.9% | 92.8% | 93.2% | 93.1% | 93.2% | 94.0%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.0% | 28.7% | 25.7% | 23.3% | 22.3% | 78.5% | 83.5% | 85.2% | 85.9% | 88.0%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 23.7% | 24.3% | 23.0% | 22.3% | 21.7% | 53.7% | 61.3% | 66.0% | 69.6% | 72.6%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.5% | 95.5% | 95.1% | 94.8% | 95.2% | 96.7% | 96.6% | 96.1% | 95.7% | 96.1%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 90.4% | 91.9% | 92.8% | 94.0% | 93.6% | 90.7% | 92.1% | 93.2% | 94.2% | 94.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 75.2% | 81.2% | 84.1% | 87.5% | 89.0% | 75.7% | 81.4% | 84.1% | 87.6% | 89.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.4% | 60.0% | 56.3% | 54.7% | 53.6% | 92.3% | 93.0% | 93.8% | 94.2% | 93.7%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 60.4% | 59.0% | 55.4% | 55.1% | 52.9% | 78.1% | 82.5% | 85.3% | 86.8% | 88.3%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 46.0% | 46.8% | 48.5% | 47.8% | 47.4% | 53.0% | 58.7% | 64.3% | 68.8% | 71.9%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.1% | 40.0% | 39.4% | 37.0% | 36.3% | 92.6% | 92.9% | 94.3% | 93.6% | 94.0%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 42.0% | 41.8% | 40.0% | 37.4% | 36.8% | 76.9% | 81.7% | 84.9% | 85.7% | 87.0%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 33.7% | 33.1% | 33.4% | 32.7% | 33.6% | 50.2% | 57.9% | 63.6% | 67.6% | 69.4%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.5% | 26.3% | 23.3% | 23.2% | 21.6% | 93.2% | 93.4% | 92.8% | 93.6% | 94.1%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.3% | 27.2% | 25.7% | 23.1% | 22.1% | 78.1% | 80.9% | 83.9% | 85.6% | 85.5%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 22.6% | 22.6% | 22.6% | 21.1% | 21.2% | 49.9% | 56.7% | 62.4% | 65.0% | 68.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.5% | 94.9% | 95.2% | 94.8% | 94.8% | 95.9% | 96.0% | 96.4% | 95.6% | 95.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 88.7% | 91.2% | 92.3% | 93.3% | 93.2% | 89.2% | 91.5% | 92.7% | 93.4% | 93.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 71.3% | 76.6% | 81.2% | 83.9% | 87.1% | 71.9% | 76.5% | 81.1% | 83.9% | 86.8%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.0% | 60.3% | 56.5% | 55.4% | 53.3% | 92.4% | 93.3% | 93.4% | 93.5% | 93.8%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 58.8% | 56.4% | 55.5% | 54.2% | 52.0% | 75.5% | 79.5% | 82.4% | 85.0% | 86.9%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 40.7% | 40.5% | 43.3% | 46.1% | 44.5% | 48.1% | 51.9% | 58.0% | 63.7% | 66.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.5% | 41.3% | 39.2% | 36.5% | 36.1% | 92.5% | 93.6% | 93.1% | 93.8% | 94.2%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.3% | 40.3% | 38.4% | 36.9% | 36.5% | 74.3% | 78.2% | 81.3% | 83.6% | 85.5%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 28.8% | 29.3% | 29.6% | 30.6% | 30.0% | 43.8% | 50.0% | 56.5% | 61.9% | 63.7%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.4% | 26.4% | 24.8% | 23.4% | 22.2% | 92.7% | 93.1% | 93.3% | 93.7% | 93.1%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.1% | 26.1% | 24.6% | 23.9% | 23.2% | 76.1% | 77.5% | 81.2% | 83.6% | 84.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 19.1% | 21.1% | 20.2% | 19.6% | 19.9% | 45.6% | 52.1% | 57.3% | 60.8% | 64.6%

Table E22 Coverage probability of the estimated intercept, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.3% | 94.9% | 94.9% | 94.9% | 94.8% | 95.8% | 96.3% | 96.1% | 96.2% | 96.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.9% | 93.2% | 94.0% | 93.9% | 94.2% | 93.6% | 94.2% | 95.0% | 94.9% | 95.0%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 88.8% | 91.3% | 92.9% | 93.0% | 93.2% | 89.7% | 91.9% | 93.6% | 93.7% | 94.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.3% | 61.3% | 56.0% | 54.1% | 51.7% | 90.6% | 92.6% | 92.4% | 93.0% | 93.5%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.7% | 58.4% | 55.5% | 53.3% | 53.8% | 82.1% | 85.0% | 87.2% | 88.2% | 89.7%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 60.5% | 57.3% | 55.9% | 53.2% | 52.8% | 70.1% | 75.9% | 80.4% | 82.7% | 84.5%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.8% | 39.4% | 39.2% | 36.8% | 34.8% | 91.2% | 90.8% | 91.9% | 92.7% | 93.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.7% | 40.8% | 37.5% | 36.9% | 34.4% | 81.7% | 84.9% | 85.7% | 86.6% | 86.9%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 43.2% | 40.4% | 38.6% | 36.8% | 35.4% | 65.3% | 73.9% | 78.1% | 78.6% | 82.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.5% | 24.7% | 23.5% | 20.8% | 20.8% | 88.8% | 89.5% | 89.5% | 91.3% | 91.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.7% | 25.2% | 24.6% | 22.0% | 22.1% | 80.7% | 82.8% | 83.8% | 84.3% | 84.1%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.8% | 26.1% | 25.0% | 22.8% | 21.3% | 61.7% | 71.5% | 75.9% | 77.9% | 78.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.3% | 95.0% | 95.1% | 94.1% | 94.9% | 95.8% | 96.0% | 96.5% | 95.5% | 96.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.7% | 93.7% | 93.8% | 93.7% | 94.4% | 93.9% | 94.4% | 94.7% | 95.2% | 95.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.1% | 91.3% | 92.0% | 92.7% | 93.7% | 87.9% | 92.0% | 92.5% | 93.5% | 94.8%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.2% | 59.0% | 55.9% | 54.0% | 54.2% | 91.4% | 92.6% | 92.7% | 93.9% | 93.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.1% | 58.1% | 56.3% | 53.8% | 52.2% | 82.9% | 84.5% | 86.1% | 87.8% | 89.4%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 59.7% | 57.3% | 56.4% | 54.0% | 51.5% | 69.5% | 75.0% | 80.6% | 82.3% | 84.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 42.2% | 39.8% | 37.7% | 36.3% | 36.3% | 90.1% | 91.1% | 92.3% | 92.8% | 92.7%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 46.7% | 41.4% | 37.8% | 36.6% | 35.2% | 81.8% | 83.2% | 85.6% | 86.2% | 87.3%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 41.8% | 40.3% | 39.5% | 35.0% | 34.6% | 64.4% | 72.8% | 76.9% | 78.9% | 81.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.2% | 23.5% | 22.8% | 22.7% | 21.2% | 89.7% | 89.2% | 90.4% | 91.3% | 91.5%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.9% | 26.8% | 24.1% | 21.0% | 21.0% | 80.2% | 82.4% | 83.8% | 84.5% | 85.2%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 27.0% | 25.7% | 25.0% | 23.4% | 22.4% | 61.9% | 70.5% | 75.0% | 77.3% | 78.6%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 95.3% | 94.9% | 94.8% | 94.7% | 95.8% | 96.4% | 96.1% | 96.2% | 95.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.3% | 93.2% | 94.1% | 94.7% | 94.5% | 93.4% | 94.3% | 95.0% | 95.6% | 95.5%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 86.1% | 89.5% | 91.5% | 92.6% | 93.6% | 86.9% | 90.4% | 92.3% | 93.5% | 94.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.5% | 58.6% | 57.0% | 55.0% | 52.2% | 91.0% | 91.9% | 92.5% | 93.4% | 94.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.2% | 58.7% | 56.5% | 53.5% | 52.4% | 81.8% | 84.8% | 86.1% | 88.4% | 89.3%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 57.0% | 56.8% | 55.1% | 53.7% | 52.0% | 67.3% | 74.4% | 79.1% | 82.1% | 83.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.4% | 41.0% | 39.2% | 37.1% | 35.2% | 90.3% | 91.4% | 91.9% | 92.9% | 92.1%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.5% | 40.9% | 38.0% | 36.2% | 35.7% | 80.5% | 83.7% | 84.5% | 85.5% | 86.9%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 40.1% | 39.5% | 37.1% | 36.1% | 34.6% | 60.3% | 72.3% | 76.2% | 79.3% | 81.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.9% | 25.8% | 22.6% | 23.2% | 22.3% | 89.4% | 90.0% | 90.6% | 91.1% | 91.5%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.0% | 26.8% | 24.3% | 22.7% | 20.5% | 79.7% | 82.1% | 82.4% | 83.5% | 84.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.4% | 24.9% | 25.5% | 23.5% | 21.5% | 59.7% | 69.4% | 75.2% | 76.7% | 78.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.3% | 95.3% | 94.9% | 94.7% | 95.2% | 96.6% | 96.7% | 96.1% | 95.8% | 96.3%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.1% | 93.1% | 93.3% | 94.5% | 94.4% | 92.0% | 93.8% | 94.4% | 95.1% | 95.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 82.0% | 87.6% | 90.5% | 91.3% | 92.4% | 82.9% | 88.4% | 91.0% | 91.8% | 92.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.6% | 59.5% | 56.0% | 54.6% | 53.5% | 91.5% | 92.2% | 93.2% | 93.7% | 93.4%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 60.3% | 59.1% | 55.6% | 54.8% | 53.1% | 80.9% | 84.6% | 86.8% | 87.8% | 88.4%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 52.3% | 53.1% | 52.9% | 52.3% | 50.4% | 63.0% | 70.7% | 75.6% | 79.4% | 81.5%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.9% | 38.9% | 39.1% | 36.9% | 36.1% | 90.7% | 91.2% | 92.5% | 92.5% | 92.9%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 42.8% | 41.5% | 38.4% | 36.1% | 36.2% | 78.8% | 83.4% | 84.7% | 85.3% | 86.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 37.9% | 39.0% | 37.1% | 35.2% | 35.2% | 60.2% | 70.7% | 74.6% | 76.8% | 78.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.9% | 25.6% | 22.7% | 22.5% | 21.4% | 90.1% | 90.7% | 90.2% | 91.0% | 91.7%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.3% | 25.8% | 24.9% | 22.0% | 20.5% | 79.2% | 81.1% | 83.0% | 82.9% | 83.7%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.0% | 25.1% | 23.8% | 22.2% | 21.0% | 58.9% | 65.9% | 72.1% | 73.7% | 75.7%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 94.7% | 95.1% | 94.6% | 94.7% | 95.7% | 95.9% | 96.4% | 95.8% | 95.8%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 90.5% | 92.5% | 93.6% | 94.7% | 93.9% | 91.3% | 93.3% | 94.3% | 95.2% | 94.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 79.4% | 85.1% | 87.8% | 89.6% | 91.6% | 80.6% | 86.0% | 88.6% | 90.1% | 92.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.0% | 59.9% | 56.2% | 55.3% | 53.2% | 91.7% | 92.9% | 92.9% | 93.1% | 93.2%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 61.0% | 57.8% | 56.2% | 54.8% | 53.0% | 79.8% | 83.4% | 85.2% | 87.0% | 88.2%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 49.2% | 49.6% | 50.2% | 52.2% | 49.8% | 59.9% | 68.5% | 72.5% | 78.1% | 78.2%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.2% | 41.0% | 39.4% | 35.9% | 35.6% | 90.2% | 92.0% | 91.4% | 92.2% | 93.1%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.8% | 41.3% | 39.7% | 38.0% | 36.2% | 77.3% | 81.4% | 83.7% | 84.9% | 85.2%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 34.7% | 35.1% | 35.8% | 34.9% | 33.6% | 55.7% | 65.6% | 71.3% | 74.4% | 76.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.4% | 25.3% | 24.0% | 23.0% | 22.1% | 89.7% | 89.8% | 90.7% | 91.2% | 90.9%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.1% | 25.1% | 24.5% | 23.1% | 22.4% | 77.9% | 79.0% | 81.8% | 83.4% | 83.4%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 22.3% | 23.9% | 22.8% | 21.4% | 21.4% | 55.5% | 64.9% | 69.4% | 71.1% | 74.6%

Table E23 Coverage probability of the estimated intercept, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.9% | 94.4% | 94.2% | 94.2% | 94.3% | 95.4% | 96.0% | 95.7% | 96.0% | 95.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.3% | 93.2% | 93.7% | 93.8% | 93.7% | 94.1% | 94.1% | 94.6% | 94.8% | 94.7%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 88.8% | 91.6% | 93.5% | 93.2% | 92.8% | 89.5% | 92.4% | 94.2% | 93.9% | 93.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.6% | 59.7% | 54.3% | 51.8% | 49.7% | 89.1% | 90.7% | 89.3% | 90.0% | 89.7%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.3% | 58.5% | 55.3% | 52.9% | 52.3% | 82.5% | 84.8% | 86.9% | 87.1% | 87.9%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 60.3% | 57.6% | 56.2% | 53.4% | 52.3% | 69.9% | 74.9% | 79.4% | 81.5% | 83.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 41.7% | 37.3% | 36.8% | 34.9% | 32.3% | 88.1% | 87.6% | 86.7% | 87.2% | 87.2%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.8% | 42.2% | 36.5% | 35.5% | 32.9% | 81.5% | 84.6% | 84.2% | 85.3% | 85.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 42.3% | 39.7% | 38.2% | 35.7% | 34.5% | 63.5% | 72.3% | 77.1% | 78.2% | 80.4%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.3% | 23.3% | 21.8% | 19.2% | 19.5% | 85.5% | 84.8% | 84.2% | 83.5% | 83.3%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 30.2% | 25.5% | 24.5% | 22.0% | 21.4% | 80.8% | 82.4% | 83.3% | 83.0% | 82.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.0% | 25.0% | 24.4% | 22.7% | 21.0% | 60.8% | 69.7% | 74.2% | 76.8% | 77.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.1% | 94.5% | 94.6% | 93.7% | 94.6% | 95.7% | 95.7% | 96.2% | 95.4% | 96.0%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.2% | 93.8% | 93.4% | 93.7% | 94.0% | 94.1% | 94.8% | 94.6% | 94.7% | 94.8%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.4% | 91.4% | 92.1% | 93.0% | 93.6% | 88.0% | 92.1% | 92.6% | 93.6% | 94.7%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.0% | 57.4% | 54.6% | 52.1% | 52.9% | 90.0% | 90.9% | 90.1% | 90.6% | 90.6%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 63.3% | 57.7% | 55.8% | 52.1% | 50.8% | 82.0% | 84.2% | 85.1% | 86.4% | 87.5%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 58.9% | 56.9% | 55.5% | 53.7% | 50.9% | 69.0% | 73.6% | 79.4% | 81.3% | 82.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 41.2% | 37.6% | 35.6% | 33.7% | 34.3% | 88.0% | 88.1% | 87.6% | 87.5% | 86.6%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 46.7% | 41.0% | 37.0% | 35.7% | 34.1% | 81.5% | 83.3% | 85.1% | 84.9% | 85.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 41.0% | 40.0% | 39.2% | 35.1% | 33.8% | 63.3% | 71.5% | 76.0% | 77.9% | 80.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.1% | 22.8% | 21.2% | 21.2% | 19.8% | 86.5% | 84.7% | 85.3% | 84.5% | 84.1%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.7% | 26.7% | 24.3% | 21.2% | 20.0% | 80.9% | 82.2% | 83.2% | 83.1% | 83.4%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 26.3% | 25.0% | 23.8% | 23.5% | 21.5% | 60.4% | 69.4% | 73.1% | 76.3% | 77.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.7% | 95.0% | 94.2% | 94.1% | 94.1% | 95.4% | 96.2% | 95.7% | 96.0% | 95.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.5% | 93.2% | 93.6% | 94.5% | 93.8% | 93.5% | 94.2% | 94.7% | 95.2% | 95.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 86.3% | 89.5% | 90.9% | 92.1% | 93.2% | 86.9% | 90.2% | 91.7% | 92.8% | 93.9%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.9% | 57.2% | 55.1% | 53.5% | 50.6% | 89.3% | 89.6% | 90.2% | 90.6% | 91.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 62.2% | 58.5% | 55.8% | 52.9% | 51.2% | 81.8% | 84.3% | 85.0% | 87.1% | 87.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 56.3% | 55.7% | 53.8% | 52.9% | 51.0% | 66.6% | 72.5% | 77.3% | 80.6% | 82.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 42.7% | 39.0% | 36.9% | 35.2% | 33.0% | 87.7% | 87.4% | 87.2% | 86.6% | 86.6%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 45.3% | 40.3% | 37.3% | 35.9% | 34.1% | 80.1% | 82.9% | 83.4% | 84.0% | 85.2%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 39.5% | 38.5% | 36.1% | 35.3% | 34.2% | 59.4% | 70.2% | 74.4% | 77.5% | 79.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.2% | 24.5% | 21.2% | 21.1% | 20.1% | 85.2% | 85.9% | 84.1% | 83.4% | 83.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 27.8% | 26.7% | 23.4% | 22.0% | 19.9% | 79.7% | 81.4% | 82.2% | 81.8% | 82.0%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 25.0% | 24.6% | 24.1% | 22.2% | 21.5% | 58.9% | 67.4% | 72.6% | 74.4% | 75.9%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.9% | 94.7% | 94.4% | 94.2% | 94.4% | 96.4% | 96.2% | 95.7% | 95.5% | 95.9%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.4% | 92.3% | 92.8% | 94.0% | 93.8% | 92.2% | 92.9% | 93.9% | 94.7% | 94.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 81.9% | 86.7% | 89.6% | 90.7% | 91.6% | 82.6% | 87.8% | 90.4% | 91.3% | 92.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 61.1% | 57.6% | 54.3% | 52.4% | 51.2% | 89.8% | 89.8% | 90.6% | 90.7% | 89.6%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 60.5% | 57.6% | 54.0% | 53.4% | 51.6% | 80.8% | 83.3% | 85.1% | 85.6% | 86.5%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 51.1% | 51.3% | 51.1% | 49.9% | 48.2% | 61.7% | 68.3% | 72.9% | 77.1% | 79.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 42.5% | 36.9% | 36.8% | 34.5% | 34.2% | 87.9% | 87.8% | 88.1% | 87.0% | 87.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 41.7% | 40.7% | 37.6% | 35.2% | 34.0% | 78.2% | 82.4% | 83.4% | 83.3% | 83.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 36.9% | 37.4% | 35.4% | 33.7% | 32.3% | 58.0% | 67.3% | 71.1% | 74.0% | 74.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.5% | 23.9% | 21.1% | 20.6% | 19.6% | 86.3% | 86.5% | 83.9% | 83.8% | 83.2%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 28.7% | 25.5% | 23.6% | 21.1% | 20.1% | 78.8% | 80.5% | 81.8% | 81.7% | 81.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 23.9% | 23.7% | 22.9% | 21.2% | 20.3% | 56.5% | 63.5% | 69.3% | 71.1% | 73.4%
β_1_ = 0.444 | τ^2^ = 0 = 0 | Number of Missing Studies | 0 | 93.7% | 94.3% | 94.6% | 94.2% | 94.3% | 95.4% | 95.7% | 96.1% | 95.7% | 95.7%
β_1_ = 0.444 | τ^2^ = 0 = 0 | Number of Missing Studies | 5 | 89.7% | 91.8% | 92.8% | 94.1% | 93.3% | 90.5% | 92.8% | 93.9% | 94.5% | 94.2%
β_1_ = 0.444 | τ^2^ = 0 = 0 | Number of Missing Studies | 10 | 78.8% | 84.3% | 87.6% | 89.6% | 90.9% | 79.9% | 85.0% | 88.2% | 90.1% | 91.6%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 60.7% | 58.4% | 54.5% | 53.8% | 51.6% | 90.0% | 90.5% | 90.7% | 90.2% | 90.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 59.9% | 56.4% | 54.8% | 53.2% | 50.6% | 78.7% | 81.7% | 83.7% | 84.9% | 86.0%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 47.9% | 48.3% | 48.0% | 50.6% | 47.9% | 58.7% | 65.3% | 69.8% | 76.0% | 75.7%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 41.6% | 39.2% | 37.3% | 33.9% | 33.0% | 87.9% | 88.3% | 87.5% | 87.6% | 86.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 43.1% | 40.1% | 37.5% | 35.7% | 34.2% | 76.5% | 80.8% | 81.9% | 83.3% | 82.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 32.6% | 32.5% | 33.9% | 33.2% | 31.9% | 53.3% | 62.4% | 67.7% | 71.4% | 72.5%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 26.6% | 23.5% | 22.5% | 20.9% | 19.9% | 86.6% | 85.2% | 84.2% | 84.1% | 82.3%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 29.7% | 24.8% | 23.2% | 22.7% | 21.6% | 77.4% | 78.5% | 80.6% | 81.3% | 81.0%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 21.0% | 22.2% | 21.6% | 20.2% | 19.7% | 54.2% | 61.3% | 66.1% | 68.7% | 71.7%

Table E24 Absolute bias in the estimated slope, with no correction for publication bias (from 2-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.001 | 0.002 | -0.002 | -0.001 | 0.000 | -0.001 | 0.001 | -0.003 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.009 | -0.006 | -0.006 | -0.002 | -0.001 | -0.009 | -0.007 | -0.006 | -0.003 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.025 | -0.016 | -0.008 | -0.006 | -0.005 | -0.026 | -0.016 | -0.008 | -0.006 | -0.005
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.003 | -0.002 | 0.000 | -0.003 | -0.001 | -0.003 | 0.002 | 0.001 | -0.004 | 0.002
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.018 | -0.009 | -0.010 | -0.010 | 0.000 | -0.020 | -0.007 | -0.009 | -0.011 | -0.005
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.024 | -0.020 | -0.013 | -0.019 | -0.011 | -0.022 | -0.020 | -0.014 | -0.018 | -0.012
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.005 | 0.016 | -0.002 | 0.004 | 0.001 | -0.003 | 0.001 | -0.001 | 0.003 | 0.003
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.023 | -0.009 | -0.008 | -0.006 | -0.006 | -0.020 | -0.012 | -0.012 | -0.010 | -0.010
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.021 | -0.014 | -0.016 | -0.019 | -0.004 | -0.025 | -0.020 | -0.018 | -0.022 | -0.015
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.000 | 0.024 | 0.007 | -0.003 | -0.001 | -0.007 | 0.011 | 0.000 | 0.000 | 0.003
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.002 | -0.018 | -0.017 | -0.022 | -0.013 | -0.012 | -0.022 | -0.018 | -0.018 | -0.008
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.041 | -0.023 | -0.024 | -0.017 | -0.009 | -0.028 | -0.033 | -0.023 | -0.019 | -0.008
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | 0.003 | 0.002 | -0.001 | -0.001 | 0.000 | 0.003 | 0.002 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.011 | -0.007 | -0.004 | -0.003 | -0.005 | -0.011 | -0.008 | -0.004 | -0.003 | -0.004
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.047 | -0.024 | -0.015 | -0.010 | -0.008 | -0.047 | -0.024 | -0.015 | -0.011 | -0.008
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.007 | -0.005 | 0.001 | 0.002 | -0.001 | -0.005 | -0.007 | 0.002 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.016 | -0.020 | -0.014 | -0.011 | -0.008 | -0.021 | -0.022 | -0.017 | -0.014 | -0.009
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.040 | -0.030 | -0.025 | -0.023 | -0.015 | -0.041 | -0.032 | -0.027 | -0.022 | -0.020
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.000 | 0.004 | 0.010 | 0.001 | -0.002 | -0.001 | -0.003 | 0.002 | 0.000 | -0.002
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.020 | -0.020 | -0.018 | -0.015 | -0.001 | -0.025 | -0.014 | -0.025 | -0.017 | -0.008
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.047 | -0.038 | -0.021 | -0.045 | -0.027 | -0.043 | -0.033 | -0.029 | -0.032 | -0.022
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.008 | 0.005 | -0.003 | -0.005 | 0.006 | -0.004 | 0.001 | -0.011 | -0.006 | -0.002
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.020 | -0.023 | -0.010 | -0.027 | -0.024 | -0.022 | -0.026 | -0.022 | -0.022 | -0.015
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.034 | -0.031 | -0.041 | -0.023 | -0.019 | -0.048 | -0.032 | -0.039 | -0.030 | -0.021
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | 0.000 | -0.001 | 0.001 | 0.001 | -0.002 | -0.001 | -0.001 | 0.001 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.027 | -0.014 | -0.012 | -0.007 | -0.007 | -0.028 | -0.014 | -0.012 | -0.007 | -0.006
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.087 | -0.044 | -0.030 | -0.018 | -0.014 | -0.087 | -0.045 | -0.030 | -0.019 | -0.014
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.007 | 0.003 | 0.003 | -0.007 | -0.002 | 0.003 | -0.004 | -0.002 | -0.003 | -0.003
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.041 | -0.039 | -0.017 | -0.015 | -0.015 | -0.046 | -0.040 | -0.024 | -0.021 | -0.020
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.083 | -0.061 | -0.049 | -0.037 | -0.039 | -0.085 | -0.061 | -0.051 | -0.043 | -0.044
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.005 | -0.005 | -0.004 | 0.002 | 0.002 | 0.012 | -0.003 | -0.001 | 0.000 | 0.000
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.058 | -0.032 | -0.029 | -0.026 | -0.024 | -0.060 | -0.043 | -0.033 | -0.033 | -0.028
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.083 | -0.071 | -0.058 | -0.054 | -0.047 | -0.086 | -0.065 | -0.058 | -0.054 | -0.047
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.018 | 0.010 | 0.009 | -0.002 | -0.006 | 0.005 | -0.001 | -0.002 | 0.006 | -0.003
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.071 | -0.053 | -0.039 | -0.031 | -0.032 | -0.065 | -0.046 | -0.049 | -0.043 | -0.029
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.092 | -0.067 | -0.054 | -0.053 | -0.059 | -0.087 | -0.066 | -0.067 | -0.054 | -0.058
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | 0.002 | 0.001 | -0.002 | 0.001 | -0.003 | 0.003 | 0.001 | -0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.059 | -0.032 | -0.022 | -0.016 | -0.013 | -0.060 | -0.034 | -0.023 | -0.017 | -0.014
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.163 | -0.085 | -0.057 | -0.038 | -0.031 | -0.164 | -0.086 | -0.058 | -0.039 | -0.032
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | 0.005 | 0.003 | 0.001 | 0.005 | 0.000 | -0.001 | 0.004 | 0.000 | 0.002
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.082 | -0.066 | -0.049 | -0.030 | -0.028 | -0.091 | -0.070 | -0.057 | -0.046 | -0.042
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.174 | -0.127 | -0.098 | -0.084 | -0.066 | -0.173 | -0.127 | -0.102 | -0.090 | -0.077
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.009 | -0.007 | -0.001 | -0.003 | 0.004 | 0.003 | -0.002 | -0.003 | 0.002 | 0.001
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.108 | -0.076 | -0.054 | -0.046 | -0.046 | -0.108 | -0.086 | -0.060 | -0.067 | -0.055
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.150 | -0.128 | -0.111 | -0.087 | -0.084 | -0.156 | -0.131 | -0.116 | -0.099 | -0.093
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.009 | 0.021 | 0.000 | 0.010 | 0.011 | -0.001 | 0.010 | 0.000 | -0.003 | 0.004
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.109 | -0.105 | -0.085 | -0.075 | -0.060 | -0.111 | -0.102 | -0.086 | -0.071 | -0.070
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.159 | -0.139 | -0.121 | -0.112 | -0.091 | -0.162 | -0.145 | -0.122 | -0.114 | -0.095
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.003 | 0.001 | -0.002 | 0.001 | 0.000 | 0.003 | 0.001 | -0.002 | 0.001 | 0.000
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.077 | -0.046 | -0.030 | -0.023 | -0.019 | -0.079 | -0.048 | -0.031 | -0.024 | -0.020
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.222 | -0.126 | -0.081 | -0.059 | -0.043 | -0.223 | -0.129 | -0.083 | -0.060 | -0.044
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | -0.002 | -0.003 | 0.001 | 0.004 | 0.000 | -0.004 | -0.003 | -0.001 | 0.006
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.132 | -0.091 | -0.063 | -0.048 | -0.037 | -0.140 | -0.101 | -0.080 | -0.066 | -0.055
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.241 | -0.181 | -0.136 | -0.109 | -0.093 | -0.242 | -0.186 | -0.149 | -0.125 | -0.111
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.012 | 0.010 | 0.003 | 0.001 | 0.004 | 0.008 | 0.003 | -0.004 | -0.004 | -0.004
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.143 | -0.125 | -0.095 | -0.084 | -0.061 | -0.152 | -0.130 | -0.108 | -0.097 | -0.078
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.254 | -0.205 | -0.168 | -0.131 | -0.129 | -0.256 | -0.204 | -0.175 | -0.148 | -0.139
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.003 | 0.010 | 0.000 | 0.008 | 0.007 | -0.007 | 0.000 | -0.002 | -0.006 | 0.005
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.163 | -0.153 | -0.110 | -0.098 | -0.092 | -0.167 | -0.154 | -0.118 | -0.102 | -0.099
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.254 | -0.206 | -0.198 | -0.171 | -0.154 | -0.258 | -0.212 | -0.189 | -0.168 | -0.153

Table E25 Absolute bias in the estimated slope, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.001 | 0.001 | -0.002 | -0.001 | 0.000 | -0.001 | 0.001 | -0.003 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.008 | -0.006 | -0.006 | -0.002 | 0.000 | -0.008 | -0.006 | -0.005 | -0.003 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.015 | -0.010 | -0.006 | -0.004 | -0.004 | -0.014 | -0.010 | -0.007 | -0.004 | -0.004
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.002 | -0.002 | 0.001 | -0.004 | -0.001 | -0.003 | 0.002 | 0.002 | -0.005 | 0.001
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.012 | -0.003 | -0.009 | -0.008 | 0.000 | -0.013 | 0.000 | -0.006 | -0.008 | -0.005
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.016 | -0.015 | -0.008 | -0.017 | -0.007 | -0.012 | -0.012 | -0.006 | -0.014 | -0.005
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.004 | 0.016 | -0.002 | 0.004 | 0.001 | -0.004 | 0.003 | -0.001 | 0.003 | 0.003
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.019 | -0.004 | -0.009 | -0.005 | -0.005 | -0.013 | -0.010 | -0.010 | -0.006 | -0.007
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.015 | -0.007 | -0.007 | -0.017 | -0.002 | -0.018 | -0.009 | -0.011 | -0.018 | -0.011
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.001 | 0.016 | 0.005 | -0.003 | 0.000 | -0.008 | 0.000 | -0.003 | -0.002 | 0.004
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.001 | -0.010 | -0.013 | -0.019 | -0.006 | -0.012 | -0.012 | -0.013 | -0.013 | 0.003
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.029 | -0.016 | -0.017 | -0.011 | -0.004 | -0.010 | -0.021 | -0.017 | -0.011 | 0.002
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.002 | 0.003 | 0.001 | -0.001 | -0.001 | -0.002 | 0.003 | 0.002 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.006 | -0.005 | -0.004 | -0.002 | -0.004 | -0.006 | -0.006 | -0.004 | -0.003 | -0.005
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.029 | -0.016 | -0.013 | -0.008 | -0.006 | -0.028 | -0.015 | -0.014 | -0.008 | -0.006
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.007 | -0.005 | 0.001 | 0.001 | -0.001 | -0.005 | -0.007 | 0.001 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.012 | -0.017 | -0.011 | -0.008 | -0.005 | -0.015 | -0.018 | -0.011 | -0.008 | -0.006
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.025 | -0.022 | -0.018 | -0.016 | -0.011 | -0.024 | -0.022 | -0.017 | -0.014 | -0.011
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.001 | 0.007 | 0.009 | 0.000 | -0.003 | 0.001 | -0.001 | 0.000 | 0.000 | -0.002
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.020 | -0.012 | -0.011 | -0.011 | 0.006 | -0.024 | -0.007 | -0.018 | -0.011 | 0.000
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.033 | -0.026 | -0.013 | -0.033 | -0.017 | -0.028 | -0.016 | -0.022 | -0.019 | -0.010
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.002 | 0.002 | -0.002 | -0.006 | 0.005 | -0.006 | -0.001 | -0.014 | -0.011 | -0.004
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.012 | -0.017 | -0.006 | -0.027 | -0.021 | -0.005 | -0.019 | -0.018 | -0.017 | -0.008
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.026 | -0.023 | -0.032 | -0.014 | -0.017 | -0.041 | -0.016 | -0.020 | -0.018 | -0.018
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.001 | -0.001 | 0.001 | 0.001 | -0.002 | -0.001 | -0.001 | 0.001 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.022 | -0.010 | -0.009 | -0.005 | -0.006 | -0.023 | -0.010 | -0.010 | -0.006 | -0.006
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.053 | -0.028 | -0.021 | -0.014 | -0.010 | -0.052 | -0.028 | -0.022 | -0.015 | -0.012
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.007 | 0.002 | 0.002 | -0.007 | -0.002 | 0.004 | -0.005 | -0.002 | -0.003 | -0.004
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.029 | -0.028 | -0.012 | -0.011 | -0.013 | -0.029 | -0.024 | -0.016 | -0.013 | -0.015
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.061 | -0.039 | -0.035 | -0.024 | -0.030 | -0.059 | -0.033 | -0.030 | -0.025 | -0.031
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.006 | -0.006 | -0.005 | 0.001 | 0.001 | 0.013 | -0.005 | 0.000 | -0.002 | 0.000
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.045 | -0.024 | -0.021 | -0.020 | -0.017 | -0.042 | -0.028 | -0.024 | -0.021 | -0.019
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.067 | -0.054 | -0.040 | -0.038 | -0.035 | -0.064 | -0.038 | -0.035 | -0.034 | -0.030
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.018 | 0.007 | 0.010 | 0.000 | -0.004 | 0.006 | -0.003 | -0.006 | 0.008 | -0.003
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.061 | -0.039 | -0.030 | -0.020 | -0.025 | -0.051 | -0.025 | -0.034 | -0.029 | -0.017
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.072 | -0.049 | -0.037 | -0.036 | -0.048 | -0.056 | -0.041 | -0.039 | -0.031 | -0.038
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | 0.002 | 0.001 | -0.002 | 0.001 | -0.002 | 0.003 | 0.001 | -0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.043 | -0.026 | -0.019 | -0.015 | -0.012 | -0.043 | -0.028 | -0.022 | -0.017 | -0.014
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.099 | -0.054 | -0.042 | -0.030 | -0.026 | -0.096 | -0.053 | -0.043 | -0.033 | -0.028
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.002 | 0.006 | 0.003 | 0.001 | 0.005 | -0.002 | 0.001 | 0.003 | 0.000 | 0.002
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.059 | -0.049 | -0.037 | -0.025 | -0.023 | -0.061 | -0.049 | -0.041 | -0.039 | -0.033
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.124 | -0.090 | -0.067 | -0.061 | -0.048 | -0.113 | -0.078 | -0.060 | -0.057 | -0.051
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.010 | -0.005 | 0.000 | -0.004 | 0.005 | 0.003 | 0.001 | -0.001 | 0.000 | 0.001
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.079 | -0.056 | -0.037 | -0.037 | -0.039 | -0.070 | -0.058 | -0.040 | -0.052 | -0.042
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.109 | -0.086 | -0.078 | -0.057 | -0.059 | -0.101 | -0.074 | -0.067 | -0.055 | -0.059
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.005 | 0.021 | 0.002 | 0.011 | 0.011 | -0.003 | 0.010 | 0.000 | -0.005 | 0.004
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.074 | -0.084 | -0.061 | -0.054 | -0.048 | -0.067 | -0.071 | -0.054 | -0.039 | -0.050
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.121 | -0.100 | -0.084 | -0.076 | -0.064 | -0.109 | -0.091 | -0.073 | -0.067 | -0.051
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.003 | 0.001 | -0.002 | 0.001 | 0.000 | 0.003 | 0.002 | -0.002 | 0.001 | 0.000
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.056 | -0.038 | -0.026 | -0.021 | -0.017 | -0.058 | -0.041 | -0.028 | -0.023 | -0.019
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.132 | -0.086 | -0.061 | -0.049 | -0.037 | -0.128 | -0.087 | -0.064 | -0.052 | -0.040
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.001 | -0.002 | -0.003 | 0.001 | 0.003 | 0.000 | -0.004 | -0.003 | -0.001 | 0.005
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.100 | -0.070 | -0.052 | -0.037 | -0.032 | -0.096 | -0.072 | -0.060 | -0.051 | -0.045
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.169 | -0.126 | -0.098 | -0.078 | -0.071 | -0.157 | -0.116 | -0.097 | -0.081 | -0.077
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.010 | 0.009 | 0.003 | 0.000 | 0.003 | 0.006 | 0.003 | -0.004 | -0.005 | -0.005
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.106 | -0.098 | -0.072 | -0.065 | -0.045 | -0.102 | -0.092 | -0.073 | -0.067 | -0.052
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.195 | -0.146 | -0.121 | -0.093 | -0.093 | -0.178 | -0.124 | -0.105 | -0.093 | -0.089
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.002 | 0.013 | 0.002 | 0.008 | 0.006 | -0.012 | 0.000 | -0.003 | -0.009 | 0.002
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.126 | -0.120 | -0.084 | -0.073 | -0.067 | -0.112 | -0.110 | -0.077 | -0.066 | -0.064
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.196 | -0.148 | -0.149 | -0.130 | -0.112 | -0.181 | -0.135 | -0.118 | -0.105 | -0.094

Table E26 Absolute bias in the estimated slope, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.000 | -0.002 | 0.002 | -0.002 | -0.001 | -0.001 | -0.002 | 0.001 | -0.003 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.009 | -0.005 | -0.006 | -0.002 | -0.001 | -0.009 | -0.006 | -0.005 | -0.002 | -0.001
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.016 | -0.011 | -0.006 | -0.004 | -0.005 | -0.016 | -0.011 | -0.007 | -0.005 | -0.004
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.004 | -0.001 | 0.001 | -0.004 | -0.001 | -0.004 | 0.002 | 0.003 | -0.005 | 0.001
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.013 | -0.004 | -0.010 | -0.009 | 0.000 | -0.015 | -0.001 | -0.008 | -0.009 | -0.005
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.019 | -0.015 | -0.009 | -0.014 | -0.009 | -0.014 | -0.012 | -0.007 | -0.013 | -0.008
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.006 | 0.014 | 0.002 | 0.002 | 0.003 | -0.004 | 0.004 | 0.003 | 0.002 | 0.007
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.017 | -0.007 | -0.009 | -0.004 | -0.005 | -0.012 | -0.010 | -0.009 | -0.007 | -0.007
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.018 | -0.008 | -0.009 | -0.017 | -0.003 | -0.020 | -0.011 | -0.012 | -0.017 | -0.012
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.010 | 0.019 | 0.008 | -0.002 | -0.002 | -0.016 | 0.001 | 0.002 | 0.001 | 0.004
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.000 | -0.013 | -0.016 | -0.018 | -0.005 | -0.013 | -0.016 | -0.014 | -0.016 | 0.002
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.033 | -0.022 | -0.020 | -0.015 | -0.006 | -0.013 | -0.027 | -0.020 | -0.016 | 0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.001 | 0.003 | 0.001 | -0.001 | -0.002 | -0.001 | 0.003 | 0.001 | -0.001 | -0.001
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.006 | -0.006 | -0.003 | -0.003 | -0.005 | -0.007 | -0.007 | -0.004 | -0.003 | -0.005
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.030 | -0.016 | -0.013 | -0.008 | -0.006 | -0.029 | -0.016 | -0.015 | -0.009 | -0.007
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.007 | -0.006 | 0.001 | 0.000 | 0.001 | -0.006 | -0.008 | 0.001 | -0.003 | 0.001
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.013 | -0.017 | -0.011 | -0.010 | -0.005 | -0.017 | -0.017 | -0.011 | -0.010 | -0.007
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.030 | -0.023 | -0.020 | -0.018 | -0.011 | -0.028 | -0.024 | -0.020 | -0.016 | -0.012
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.000 | 0.006 | 0.007 | 0.000 | -0.003 | 0.001 | -0.001 | 0.000 | 0.000 | -0.003
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.017 | -0.013 | -0.011 | -0.011 | 0.006 | -0.023 | -0.009 | -0.016 | -0.011 | 0.000
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.036 | -0.031 | -0.014 | -0.036 | -0.019 | -0.030 | -0.021 | -0.023 | -0.021 | -0.012
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.002 | 0.002 | -0.004 | -0.008 | 0.003 | -0.005 | -0.004 | -0.016 | -0.011 | -0.009
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.013 | -0.021 | -0.010 | -0.028 | -0.023 | -0.005 | -0.021 | -0.023 | -0.019 | -0.009
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.031 | -0.023 | -0.032 | -0.020 | -0.017 | -0.044 | -0.020 | -0.021 | -0.023 | -0.017
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.003 | -0.001 | -0.001 | 0.001 | 0.001 | -0.002 | 0.000 | -0.002 | 0.001 | 0.001
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.022 | -0.011 | -0.010 | -0.006 | -0.006 | -0.023 | -0.011 | -0.011 | -0.006 | -0.006
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.057 | -0.031 | -0.022 | -0.015 | -0.011 | -0.055 | -0.031 | -0.023 | -0.016 | -0.012
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.006 | 0.003 | 0.002 | -0.007 | -0.002 | 0.003 | -0.006 | -0.003 | -0.003 | -0.003
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.032 | -0.030 | -0.013 | -0.013 | -0.013 | -0.032 | -0.027 | -0.018 | -0.015 | -0.015
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.061 | -0.043 | -0.037 | -0.025 | -0.030 | -0.060 | -0.038 | -0.033 | -0.026 | -0.031
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.004 | -0.008 | -0.006 | 0.002 | 0.001 | 0.008 | -0.006 | -0.001 | -0.001 | -0.001
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.047 | -0.024 | -0.021 | -0.024 | -0.018 | -0.043 | -0.031 | -0.024 | -0.025 | -0.019
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.070 | -0.057 | -0.045 | -0.040 | -0.037 | -0.068 | -0.043 | -0.040 | -0.036 | -0.033
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.020 | 0.006 | 0.008 | 0.000 | -0.008 | 0.006 | -0.004 | -0.004 | 0.008 | -0.006
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.064 | -0.045 | -0.035 | -0.021 | -0.026 | -0.053 | -0.028 | -0.036 | -0.030 | -0.020
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.079 | -0.050 | -0.042 | -0.041 | -0.052 | -0.064 | -0.039 | -0.045 | -0.035 | -0.043
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.001 | -0.002 | 0.003 | 0.002 | -0.002 | 0.001 | -0.003 | 0.003 | 0.002 | -0.002
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.045 | -0.027 | -0.019 | -0.015 | -0.012 | -0.045 | -0.029 | -0.022 | -0.017 | -0.014
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.105 | -0.058 | -0.044 | -0.031 | -0.026 | -0.100 | -0.058 | -0.045 | -0.033 | -0.029
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.001 | 0.006 | 0.003 | 0.001 | 0.005 | 0.000 | -0.001 | 0.003 | 0.000 | 0.002
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.063 | -0.052 | -0.038 | -0.027 | -0.023 | -0.065 | -0.051 | -0.041 | -0.039 | -0.034
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.131 | -0.095 | -0.073 | -0.065 | -0.051 | -0.120 | -0.083 | -0.065 | -0.060 | -0.054
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.011 | -0.007 | 0.002 | -0.003 | 0.004 | 0.006 | 0.001 | -0.001 | 0.001 | 0.000
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.085 | -0.058 | -0.039 | -0.039 | -0.038 | -0.076 | -0.061 | -0.041 | -0.053 | -0.042
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.116 | -0.097 | -0.084 | -0.064 | -0.064 | -0.110 | -0.086 | -0.073 | -0.063 | -0.065
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.000 | 0.020 | 0.006 | 0.017 | 0.009 | 0.007 | 0.004 | 0.001 | 0.002 | 0.003
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.081 | -0.088 | -0.061 | -0.062 | -0.049 | -0.074 | -0.076 | -0.057 | -0.048 | -0.052
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.130 | -0.109 | -0.093 | -0.083 | -0.069 | -0.116 | -0.102 | -0.080 | -0.075 | -0.060
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.004 | 0.001 | -0.002 | 0.001 | 0.000 | 0.004 | 0.002 | -0.002 | 0.002 | 0.000
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -0.057 | -0.038 | -0.025 | -0.021 | -0.018 | -0.059 | -0.040 | -0.027 | -0.023 | -0.020
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -0.138 | -0.087 | -0.062 | -0.048 | -0.035 | -0.133 | -0.088 | -0.064 | -0.051 | -0.038
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.000 | -0.001 | -0.004 | 0.001 | 0.004 | -0.002 | -0.004 | -0.003 | 0.000 | 0.004
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -0.102 | -0.071 | -0.051 | -0.039 | -0.033 | -0.097 | -0.073 | -0.060 | -0.051 | -0.044
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -0.178 | -0.132 | -0.102 | -0.082 | -0.073 | -0.164 | -0.122 | -0.101 | -0.084 | -0.078
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.012 | 0.007 | 0.004 | -0.001 | 0.006 | 0.008 | 0.003 | -0.004 | -0.007 | -0.003
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -0.110 | -0.101 | -0.074 | -0.065 | -0.045 | -0.105 | -0.095 | -0.075 | -0.067 | -0.053
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -0.204 | -0.158 | -0.128 | -0.102 | -0.100 | -0.188 | -0.136 | -0.115 | -0.102 | -0.096
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.005 | 0.017 | -0.001 | 0.007 | 0.001 | -0.014 | 0.006 | -0.004 | -0.011 | 0.002
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -0.128 | -0.122 | -0.086 | -0.075 | -0.067 | -0.113 | -0.109 | -0.080 | -0.070 | -0.064
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -0.211 | -0.162 | -0.160 | -0.137 | -0.115 | -0.195 | -0.147 | -0.132 | -0.115 | -0.101

Table E27 Coverage probability of the estimated slope, with no correction for publication bias (from 2-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.3% | 94.7% | 94.9% | 95.1% | 94.7% | 96.2% | 96.0% | 96.1% | 96.0% | 96.0%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.4% | 95.4% | 95.0% | 94.9% | 95.7% | 95.7% | 95.8% | 95.5% | 95.3% | 96.0%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 96.2% | 95.5% | 95.2% | 94.9% | 95.0% | 96.6% | 95.8% | 95.4% | 95.2% | 95.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.8% | 62.4% | 57.5% | 55.7% | 53.3% | 91.6% | 93.6% | 93.5% | 93.4% | 94.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 71.6% | 64.9% | 59.5% | 57.4% | 55.1% | 89.7% | 90.9% | 92.2% | 92.7% | 94.0%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 83.3% | 71.3% | 65.8% | 60.3% | 57.0% | 90.1% | 87.9% | 89.9% | 90.6% | 91.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.2% | 41.8% | 40.3% | 36.5% | 35.7% | 92.5% | 93.2% | 93.7% | 94.3% | 94.4%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 55.5% | 47.1% | 43.9% | 40.2% | 37.7% | 91.2% | 93.3% | 93.8% | 94.5% | 94.4%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 67.4% | 55.4% | 48.5% | 44.3% | 42.2% | 88.8% | 91.1% | 93.1% | 92.6% | 94.1%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.9% | 26.5% | 24.3% | 23.4% | 21.6% | 92.5% | 93.2% | 93.3% | 93.7% | 93.8%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 37.6% | 30.8% | 27.5% | 24.7% | 24.7% | 92.4% | 93.3% | 93.8% | 94.1% | 94.6%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 48.3% | 37.8% | 32.7% | 29.2% | 27.5% | 91.6% | 93.2% | 93.8% | 94.5% | 94.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.9% | 94.5% | 95.3% | 94.8% | 95.0% | 96.2% | 95.9% | 96.1% | 95.8% | 95.7%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.7% | 95.8% | 95.5% | 94.6% | 95.2% | 96.2% | 96.2% | 95.8% | 95.1% | 95.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 95.3% | 94.9% | 94.6% | 95.0% | 95.4% | 95.8% | 95.4% | 95.0% | 95.2% | 95.6%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.7% | 61.9% | 57.9% | 54.4% | 53.5% | 92.4% | 93.1% | 93.5% | 94.1% | 94.2%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 70.9% | 64.0% | 60.5% | 56.0% | 55.0% | 89.9% | 90.2% | 91.4% | 92.2% | 93.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 82.5% | 70.6% | 65.6% | 61.2% | 57.6% | 90.2% | 87.2% | 90.1% | 90.9% | 92.3%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.5% | 40.4% | 39.1% | 37.1% | 36.1% | 92.6% | 93.1% | 93.7% | 94.2% | 93.8%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 54.0% | 47.8% | 42.9% | 39.2% | 37.5% | 91.3% | 92.6% | 93.7% | 94.1% | 94.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 65.0% | 55.5% | 49.6% | 44.7% | 40.7% | 89.4% | 91.6% | 92.7% | 93.6% | 93.8%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 29.6% | 26.5% | 23.0% | 23.1% | 21.8% | 92.7% | 92.9% | 92.7% | 93.2% | 93.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.7% | 30.5% | 27.0% | 24.7% | 23.1% | 92.5% | 93.4% | 93.6% | 94.0% | 93.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 48.4% | 37.3% | 31.5% | 28.4% | 26.4% | 91.2% | 92.8% | 94.2% | 93.4% | 93.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 95.7% | 94.8% | 95.0% | 95.0% | 96.4% | 96.6% | 96.1% | 96.0% | 96.1%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 95.4% | 95.4% | 95.0% | 95.3% | 94.9% | 95.8% | 95.7% | 95.4% | 95.6% | 95.3%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.2% | 93.4% | 94.1% | 94.6% | 94.8% | 94.8% | 93.8% | 94.3% | 94.9% | 95.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.7% | 60.5% | 58.3% | 55.9% | 54.1% | 91.9% | 92.7% | 92.7% | 94.2% | 94.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 71.7% | 63.8% | 60.4% | 56.8% | 56.4% | 89.4% | 90.4% | 91.7% | 92.7% | 93.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 80.8% | 72.0% | 64.8% | 60.4% | 57.3% | 89.4% | 88.2% | 88.9% | 90.6% | 91.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.9% | 41.4% | 39.2% | 37.2% | 36.8% | 92.6% | 93.9% | 93.5% | 94.0% | 93.7%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 55.1% | 46.3% | 43.1% | 39.3% | 38.9% | 90.4% | 91.7% | 93.0% | 93.7% | 94.1%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 67.3% | 54.4% | 47.9% | 44.4% | 40.3% | 88.7% | 90.6% | 92.3% | 92.4% | 93.9%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.4% | 26.1% | 24.4% | 22.1% | 22.3% | 92.4% | 93.3% | 93.1% | 93.5% | 94.1%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.9% | 31.4% | 28.4% | 25.8% | 23.9% | 92.2% | 93.5% | 93.4% | 93.7% | 93.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 47.3% | 37.9% | 32.3% | 29.3% | 27.7% | 90.9% | 92.5% | 93.0% | 93.5% | 93.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.4% | 95.2% | 94.9% | 95.0% | 95.3% | 96.5% | 96.3% | 95.8% | 95.7% | 96.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 94.4% | 94.1% | 94.6% | 95.2% | 94.6% | 95.0% | 94.6% | 95.0% | 95.6% | 95.1%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 90.3% | 91.2% | 92.2% | 93.2% | 93.4% | 90.7% | 91.6% | 92.6% | 93.3% | 93.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.9% | 61.8% | 58.3% | 55.8% | 53.7% | 92.8% | 93.6% | 93.5% | 93.8% | 94.2%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 70.0% | 62.8% | 59.2% | 57.2% | 56.0% | 88.0% | 89.4% | 90.8% | 91.3% | 92.5%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 76.0% | 66.8% | 61.7% | 57.9% | 55.7% | 84.9% | 83.9% | 86.0% | 87.1% | 89.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.9% | 41.6% | 39.4% | 37.7% | 36.7% | 92.5% | 93.0% | 94.2% | 93.9% | 94.0%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.1% | 47.1% | 42.5% | 40.1% | 38.8% | 89.5% | 92.3% | 92.3% | 93.0% | 93.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.9% | 53.0% | 45.1% | 42.8% | 39.5% | 86.2% | 88.5% | 90.3% | 90.6% | 91.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.5% | 25.3% | 24.3% | 23.7% | 21.0% | 92.5% | 93.3% | 92.7% | 93.5% | 93.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 36.6% | 30.3% | 28.1% | 25.5% | 23.4% | 92.4% | 92.9% | 92.8% | 93.9% | 93.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 45.8% | 36.3% | 32.6% | 29.0% | 26.5% | 89.2% | 91.0% | 92.2% | 92.1% | 92.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.5% | 95.0% | 95.1% | 94.7% | 95.0% | 95.9% | 96.1% | 96.0% | 95.9% | 96.2%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.4% | 94.1% | 94.6% | 94.5% | 94.8% | 93.2% | 94.4% | 95.0% | 94.7% | 95.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 85.6% | 88.1% | 89.9% | 90.8% | 92.8% | 86.4% | 88.3% | 90.1% | 90.9% | 93.0%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.5% | 61.0% | 56.5% | 57.0% | 54.3% | 92.2% | 93.9% | 93.4% | 94.1% | 94.1%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 67.5% | 62.6% | 59.3% | 58.7% | 53.8% | 86.1% | 87.4% | 89.1% | 90.0% | 91.4%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 69.9% | 62.0% | 57.6% | 56.2% | 53.5% | 79.7% | 79.6% | 80.4% | 84.1% | 85.2%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.5% | 40.4% | 38.9% | 36.9% | 36.8% | 92.3% | 93.3% | 93.7% | 93.6% | 94.4%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.4% | 44.6% | 41.2% | 39.5% | 37.9% | 88.7% | 90.3% | 91.1% | 92.1% | 92.3%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 58.0% | 47.3% | 43.4% | 40.6% | 38.0% | 81.6% | 84.6% | 87.0% | 87.8% | 88.5%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.9% | 26.7% | 24.7% | 23.4% | 22.3% | 92.1% | 93.5% | 93.2% | 93.4% | 93.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.8% | 30.5% | 27.5% | 25.3% | 24.2% | 90.8% | 90.9% | 91.7% | 92.9% | 93.4%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 42.8% | 34.9% | 29.1% | 26.4% | 26.5% | 87.0% | 89.7% | 89.7% | 90.8% | 90.8%

Table E28 Coverage probability of the estimated slope, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.0% | 94.4% | 94.7% | 95.1% | 94.7% | 95.9% | 95.9% | 96.1% | 96.2% | 96.2%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.8% | 93.4% | 93.9% | 94.2% | 94.5% | 93.2% | 94.2% | 94.7% | 94.9% | 95.2%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 93.5% | 93.1% | 93.3% | 93.4% | 93.3% | 93.8% | 93.5% | 93.8% | 93.8% | 93.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.8% | 62.5% | 57.7% | 55.7% | 53.5% | 91.2% | 93.1% | 92.7% | 93.1% | 94.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.5% | 62.7% | 59.5% | 56.9% | 55.2% | 86.7% | 87.7% | 89.6% | 90.1% | 91.4%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 78.2% | 67.0% | 63.3% | 58.2% | 56.1% | 86.3% | 84.8% | 86.8% | 87.1% | 88.6%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.9% | 42.0% | 40.3% | 36.8% | 36.1% | 91.1% | 91.9% | 92.5% | 93.4% | 93.9%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.3% | 44.7% | 42.9% | 39.4% | 37.7% | 86.9% | 88.0% | 89.5% | 89.7% | 90.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 62.3% | 51.2% | 44.8% | 41.8% | 39.6% | 85.0% | 85.6% | 87.0% | 87.0% | 87.6%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.4% | 26.4% | 24.7% | 23.8% | 21.7% | 90.5% | 90.9% | 90.6% | 92.1% | 92.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.2% | 28.9% | 26.8% | 24.7% | 23.9% | 86.4% | 87.2% | 88.1% | 88.1% | 88.9%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 44.0% | 34.2% | 29.6% | 26.5% | 25.0% | 86.6% | 86.5% | 86.7% | 87.8% | 87.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.6% | 94.5% | 95.1% | 94.7% | 94.9% | 95.9% | 95.8% | 96.0% | 95.9% | 95.7%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.7% | 94.1% | 93.5% | 93.9% | 94.5% | 94.3% | 95.1% | 94.0% | 94.9% | 95.1%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 92.6% | 92.8% | 92.8% | 92.6% | 93.5% | 93.2% | 93.2% | 93.0% | 93.4% | 94.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.5% | 61.9% | 57.8% | 54.5% | 53.7% | 92.0% | 92.5% | 93.0% | 93.9% | 94.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.2% | 62.5% | 59.2% | 56.5% | 55.4% | 87.0% | 87.5% | 88.7% | 89.6% | 91.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 78.2% | 67.7% | 63.6% | 59.5% | 55.7% | 86.7% | 84.7% | 86.8% | 87.8% | 88.7%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.7% | 40.4% | 39.5% | 37.7% | 36.1% | 91.5% | 91.8% | 92.7% | 93.6% | 93.1%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.5% | 45.5% | 41.1% | 38.3% | 37.5% | 87.3% | 87.5% | 89.2% | 89.7% | 90.7%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 61.7% | 50.8% | 46.3% | 41.9% | 39.2% | 85.8% | 85.6% | 86.3% | 87.2% | 87.7%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 29.3% | 26.0% | 23.3% | 23.0% | 22.0% | 90.5% | 90.5% | 91.6% | 91.5% | 92.6%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 33.7% | 28.7% | 25.0% | 23.1% | 22.0% | 87.0% | 88.1% | 87.7% | 88.3% | 89.1%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.3% | 33.5% | 29.0% | 26.0% | 24.9% | 86.4% | 86.3% | 87.6% | 86.5% | 87.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.7% | 95.4% | 94.6% | 94.9% | 95.0% | 96.0% | 96.5% | 96.0% | 96.1% | 96.1%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.2% | 93.8% | 93.9% | 94.6% | 93.9% | 93.6% | 94.6% | 94.6% | 95.6% | 94.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 91.8% | 91.5% | 92.1% | 92.9% | 93.7% | 92.1% | 92.3% | 92.3% | 93.3% | 94.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.7% | 60.7% | 58.7% | 56.1% | 54.2% | 91.2% | 92.3% | 92.5% | 94.0% | 93.9%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 68.4% | 62.1% | 59.9% | 56.2% | 57.2% | 86.3% | 88.1% | 89.2% | 90.9% | 91.2%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 77.3% | 69.2% | 63.1% | 59.4% | 56.8% | 86.2% | 85.6% | 85.8% | 87.9% | 88.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.0% | 41.6% | 39.4% | 37.4% | 36.7% | 91.0% | 92.5% | 92.5% | 93.1% | 93.1%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.2% | 44.7% | 41.1% | 38.8% | 38.3% | 86.5% | 87.9% | 89.1% | 89.7% | 90.0%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 62.3% | 49.6% | 45.1% | 42.5% | 39.0% | 84.5% | 85.6% | 86.7% | 87.4% | 87.9%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.3% | 26.1% | 24.2% | 22.4% | 22.9% | 90.9% | 91.3% | 91.4% | 91.7% | 92.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 33.8% | 29.6% | 26.0% | 24.9% | 23.5% | 87.2% | 87.5% | 87.7% | 88.3% | 88.1%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.7% | 33.2% | 29.2% | 28.3% | 25.3% | 85.4% | 86.0% | 86.1% | 87.1% | 86.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 95.5% | 95.2% | 94.6% | 95.0% | 95.1% | 96.5% | 96.4% | 95.8% | 95.8% | 96.3%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.4% | 92.8% | 93.3% | 94.5% | 94.2% | 93.0% | 93.5% | 94.1% | 94.9% | 95.1%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 89.1% | 90.6% | 91.8% | 92.1% | 92.8% | 89.8% | 91.2% | 92.6% | 92.4% | 93.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.7% | 61.5% | 58.6% | 55.9% | 53.8% | 92.2% | 92.9% | 93.3% | 93.7% | 94.0%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 67.8% | 62.1% | 58.8% | 57.4% | 56.4% | 86.8% | 87.3% | 89.7% | 89.7% | 90.1%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 75.2% | 65.4% | 61.3% | 58.1% | 57.2% | 83.7% | 83.6% | 84.9% | 86.3% | 87.9%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.9% | 41.5% | 39.3% | 37.8% | 36.9% | 91.3% | 91.7% | 93.0% | 93.0% | 93.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.2% | 45.2% | 41.4% | 39.4% | 38.3% | 85.6% | 88.3% | 88.6% | 89.2% | 90.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 60.6% | 51.4% | 43.7% | 42.1% | 39.4% | 83.3% | 85.4% | 86.3% | 86.5% | 86.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.7% | 25.5% | 24.5% | 23.7% | 21.2% | 90.6% | 91.5% | 90.9% | 92.2% | 92.2%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 33.8% | 28.6% | 26.2% | 24.4% | 22.8% | 87.2% | 88.0% | 87.7% | 88.7% | 88.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 42.2% | 33.8% | 30.6% | 27.0% | 23.8% | 84.9% | 85.2% | 86.5% | 86.3% | 86.4%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.2% | 94.9% | 95.1% | 94.5% | 94.9% | 95.7% | 96.0% | 95.9% | 95.9% | 96.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.7% | 93.2% | 93.7% | 94.2% | 94.5% | 92.6% | 94.1% | 94.2% | 94.7% | 95.0%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.7% | 89.1% | 90.2% | 91.2% | 93.0% | 88.3% | 89.8% | 90.6% | 91.6% | 93.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.2% | 61.4% | 56.9% | 57.1% | 54.3% | 91.6% | 93.4% | 93.2% | 94.1% | 93.8%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 67.0% | 62.1% | 59.2% | 59.2% | 54.5% | 85.5% | 86.8% | 87.7% | 89.5% | 90.5%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 70.6% | 63.6% | 59.8% | 59.4% | 55.8% | 80.7% | 82.0% | 82.5% | 85.7% | 85.4%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.9% | 40.1% | 39.2% | 37.1% | 37.0% | 90.9% | 92.3% | 92.3% | 92.8% | 93.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.3% | 44.1% | 41.6% | 39.1% | 38.3% | 85.4% | 87.3% | 88.2% | 89.2% | 89.5%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 56.8% | 47.3% | 44.0% | 41.8% | 38.9% | 80.7% | 83.1% | 84.9% | 85.6% | 85.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.8% | 26.9% | 24.6% | 23.8% | 22.3% | 90.2% | 91.2% | 91.4% | 92.0% | 92.2%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.2% | 28.3% | 26.6% | 24.6% | 23.6% | 86.4% | 86.0% | 87.0% | 88.7% | 88.8%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 41.3% | 33.2% | 28.2% | 25.6% | 25.4% | 83.1% | 84.8% | 85.3% | 84.8% | 85.7%

Table E29 Coverage probability of the estimated slope, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.5% | 94.0% | 94.3% | 94.6% | 94.5% | 95.4% | 95.4% | 95.5% | 95.9% | 95.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.1% | 93.5% | 94.1% | 94.4% | 94.2% | 93.6% | 94.2% | 94.6% | 94.9% | 94.9%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 94.0% | 94.3% | 94.1% | 93.8% | 93.7% | 94.3% | 94.6% | 94.7% | 94.2% | 94.3%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.0% | 63.1% | 57.7% | 56.2% | 53.4% | 90.3% | 91.8% | 91.4% | 91.8% | 92.5%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.3% | 63.4% | 60.1% | 57.4% | 55.0% | 86.9% | 88.2% | 89.0% | 89.6% | 90.2%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 79.8% | 69.5% | 64.6% | 60.1% | 57.6% | 87.4% | 85.5% | 87.2% | 87.3% | 88.3%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.8% | 41.6% | 40.2% | 37.3% | 36.7% | 89.2% | 89.9% | 89.7% | 90.7% | 91.0%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 52.9% | 46.3% | 42.5% | 40.1% | 37.8% | 86.8% | 88.5% | 89.3% | 89.3% | 89.9%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.5% | 52.7% | 46.6% | 43.7% | 41.1% | 85.2% | 86.8% | 88.1% | 88.0% | 88.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.0% | 26.6% | 23.3% | 23.2% | 21.0% | 87.8% | 87.7% | 87.7% | 88.6% | 88.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.6% | 30.0% | 27.0% | 24.4% | 24.2% | 87.0% | 87.3% | 88.0% | 88.1% | 88.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 45.7% | 36.1% | 31.3% | 28.2% | 26.5% | 86.9% | 87.1% | 87.7% | 88.8% | 88.1%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.0% | 93.8% | 94.8% | 94.3% | 94.3% | 95.4% | 95.4% | 96.0% | 95.6% | 95.3%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 94.3% | 94.1% | 94.1% | 93.9% | 93.8% | 94.9% | 94.7% | 94.5% | 95.0% | 94.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 93.9% | 93.7% | 93.5% | 93.6% | 94.0% | 94.0% | 94.2% | 93.6% | 94.3% | 94.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.3% | 61.8% | 58.2% | 54.9% | 54.5% | 90.7% | 91.5% | 91.6% | 91.7% | 92.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.3% | 62.5% | 60.2% | 56.7% | 55.3% | 87.0% | 87.3% | 88.5% | 89.1% | 89.8%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 79.2% | 68.8% | 65.3% | 60.4% | 56.2% | 87.6% | 85.0% | 87.2% | 87.7% | 89.0%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.9% | 40.4% | 39.3% | 37.7% | 36.2% | 90.1% | 89.3% | 89.9% | 91.0% | 90.4%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.9% | 45.7% | 41.0% | 38.9% | 37.3% | 87.1% | 87.1% | 88.9% | 89.2% | 89.5%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 62.7% | 53.2% | 48.1% | 43.5% | 40.7% | 86.0% | 86.3% | 87.6% | 88.1% | 88.7%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.7% | 25.4% | 23.0% | 22.9% | 22.2% | 88.6% | 87.9% | 88.2% | 88.2% | 89.6%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.9% | 29.0% | 25.6% | 23.1% | 22.3% | 87.0% | 87.6% | 87.3% | 88.1% | 88.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 45.2% | 35.7% | 29.6% | 27.8% | 25.5% | 86.1% | 87.3% | 88.5% | 87.8% | 88.1%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.0% | 94.9% | 94.2% | 94.5% | 94.8% | 95.3% | 95.9% | 95.8% | 95.9% | 96.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 93.5% | 93.8% | 93.9% | 94.5% | 93.5% | 94.0% | 94.2% | 94.7% | 95.1% | 94.5%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 92.8% | 92.7% | 92.6% | 93.7% | 93.6% | 92.9% | 93.2% | 92.7% | 94.1% | 94.3%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 62.4% | 60.4% | 58.1% | 56.2% | 54.9% | 90.2% | 90.8% | 91.3% | 92.3% | 92.2%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.2% | 62.7% | 60.0% | 56.3% | 57.4% | 86.3% | 88.3% | 88.7% | 90.5% | 90.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 78.8% | 69.8% | 63.5% | 60.6% | 57.6% | 87.6% | 86.0% | 86.1% | 88.4% | 88.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 44.5% | 40.8% | 40.0% | 37.5% | 36.9% | 89.7% | 90.4% | 89.6% | 90.3% | 90.0%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 51.7% | 44.8% | 41.9% | 39.7% | 38.1% | 86.0% | 87.8% | 88.2% | 88.8% | 89.3%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 63.5% | 51.8% | 46.5% | 43.3% | 39.7% | 84.7% | 86.6% | 87.5% | 88.0% | 88.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 28.4% | 25.7% | 24.0% | 22.0% | 22.7% | 88.7% | 88.7% | 88.3% | 88.1% | 88.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 35.1% | 30.5% | 26.6% | 25.3% | 23.2% | 87.2% | 87.6% | 88.3% | 87.8% | 87.4%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 44.6% | 35.1% | 30.4% | 28.5% | 27.1% | 85.7% | 86.9% | 86.7% | 88.0% | 87.6%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 94.9% | 94.8% | 94.1% | 94.4% | 94.9% | 96.1% | 96.0% | 95.3% | 95.3% | 95.9%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 92.6% | 92.8% | 93.3% | 94.3% | 93.8% | 93.1% | 93.2% | 93.9% | 94.9% | 94.7%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 89.9% | 90.8% | 91.9% | 92.2% | 92.4% | 90.2% | 91.5% | 92.6% | 92.6% | 92.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 64.0% | 61.2% | 58.3% | 56.0% | 54.2% | 91.0% | 91.5% | 91.1% | 92.1% | 92.2%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 69.1% | 62.2% | 58.5% | 56.9% | 55.8% | 86.4% | 86.9% | 88.7% | 88.5% | 89.2%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 75.4% | 65.4% | 60.5% | 57.8% | 56.9% | 84.2% | 83.0% | 83.9% | 85.7% | 87.2%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 45.2% | 41.0% | 39.2% | 37.5% | 36.9% | 89.6% | 89.9% | 91.2% | 90.9% | 90.5%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 50.7% | 45.9% | 42.1% | 39.2% | 37.9% | 85.7% | 88.1% | 87.8% | 88.1% | 88.4%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 62.0% | 51.9% | 43.9% | 42.6% | 39.0% | 83.6% | 85.5% | 86.4% | 86.5% | 86.0%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.2% | 25.3% | 23.7% | 22.8% | 20.5% | 88.8% | 88.9% | 88.4% | 88.4% | 87.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.4% | 29.2% | 26.8% | 24.7% | 22.5% | 87.5% | 87.6% | 87.8% | 88.3% | 87.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 43.7% | 34.9% | 31.2% | 27.8% | 25.1% | 85.1% | 85.9% | 87.0% | 86.2% | 87.3%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 93.7% | 94.5% | 94.6% | 94.3% | 94.5% | 95.4% | 95.5% | 95.6% | 95.9% | 95.8%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 91.4% | 92.8% | 93.6% | 93.5% | 94.0% | 92.3% | 93.5% | 94.3% | 93.9% | 94.7%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 87.6% | 89.2% | 90.2% | 91.1% | 92.2% | 88.1% | 89.6% | 90.4% | 91.4% | 92.6%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 63.2% | 61.2% | 56.4% | 57.2% | 54.6% | 90.3% | 91.8% | 91.6% | 92.3% | 92.1%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 66.9% | 61.8% | 59.0% | 58.9% | 54.0% | 85.1% | 86.1% | 87.1% | 88.4% | 89.4%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 70.6% | 62.9% | 59.1% | 57.6% | 54.8% | 80.8% | 81.4% | 81.9% | 84.3% | 83.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 43.2% | 39.9% | 38.7% | 37.2% | 37.0% | 89.5% | 89.8% | 89.9% | 90.5% | 90.2%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 49.8% | 43.5% | 41.4% | 38.4% | 37.5% | 85.0% | 87.2% | 87.1% | 87.8% | 87.8%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 56.4% | 46.5% | 44.0% | 40.8% | 38.3% | 80.2% | 82.9% | 84.7% | 85.1% | 85.1%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 27.5% | 26.7% | 24.4% | 23.1% | 22.3% | 88.0% | 89.3% | 87.9% | 88.6% | 87.9%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 34.4% | 27.9% | 26.4% | 24.7% | 23.6% | 86.4% | 86.2% | 87.1% | 88.2% | 87.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 41.9% | 33.5% | 28.0% | 25.8% | 25.9% | 83.3% | 84.8% | 85.2% | 85.9% | 86.2%

Table E30 Relative bias in the estimated slope, with no correction for publication bias (from 2-dimensional algorithmic variant)

No Correction for Publication Bias | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
No Correction for Publication Bias | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.8% | -1.4% | 3.3% | -5.1% | -2.2% | 0.2% | -1.9% | 2.5% | -5.5% | -2.6%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.4% | -13.0% | -12.4% | -4.5% | -1.1% | -19.1% | -13.4% | -12.3% | -5.1% | -1.6%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -51.1% | -31.5% | -15.9% | -11.7% | -10.6% | -51.8% | -31.6% | -16.9% | -11.9% | -10.7%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -5.5% | -3.4% | 0.5% | -6.2% | -2.1% | -6.7% | 3.1% | 2.1% | -8.2% | 3.3%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -35.7% | -18.3% | -19.5% | -19.9% | -0.7% | -40.3% | -14.2% | -18.2% | -22.7% | -10.4%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -48.3% | -39.6% | -25.4% | -39.1% | -22.2% | -44.9% | -39.8% | -27.7% | -36.1% | -25.2%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -10.3% | 31.5% | -4.2% | 9.1% | 1.3% | -6.6% | 2.9% | -2.5% | 6.8% | 6.5%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -47.4% | -17.6% | -16.5% | -11.3% | -12.0% | -41.3% | -24.8% | -24.9% | -20.4% | -20.0%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -42.0% | -29.1% | -31.5% | -38.6% | -7.2% | -49.7% | -40.2% | -35.8% | -44.4% | -29.6%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.0% | 48.2% | 14.7% | -5.3% | -1.8% | -13.5% | 21.8% | 0.5% | -1.0% | 6.9%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -3.9% | -35.9% | -33.7% | -44.0% | -27.1% | -24.0% | -44.0% | -36.1% | -36.9% | -16.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -83.4% | -46.6% | -49.2% | -34.4% | -18.9% | -56.3% | -66.2% | -46.9% | -38.2% | -16.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.1% | 3.9% | 2.1% | -1.0% | -2.0% | -0.7% | 4.3% | 2.3% | -1.3% | -1.7%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.6% | -9.7% | -5.5% | -3.8% | -6.1% | -15.1% | -10.4% | -5.8% | -4.2% | -6.1%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -63.9% | -32.5% | -19.7% | -14.0% | -10.1% | -64.0% | -33.1% | -20.6% | -14.3% | -10.3%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -9.8% | -7.0% | 1.7% | 2.5% | -1.5% | -6.9% | -9.1% | 2.1% | -1.5% | -0.8%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -21.8% | -27.2% | -18.5% | -15.3% | -10.7% | -28.6% | -29.6% | -22.4% | -18.3% | -12.8%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -54.6% | -41.0% | -34.1% | -30.8% | -20.6% | -55.4% | -42.6% | -36.8% | -29.9% | -26.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.2% | 6.0% | 13.2% | 1.1% | -3.3% | -0.9% | -3.5% | 2.7% | -0.3% | -2.6%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -27.7% | -26.5% | -24.3% | -20.2% | -1.7% | -34.1% | -19.3% | -33.7% | -23.0% | -11.2%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -63.4% | -51.7% | -27.7% | -60.5% | -36.6% | -58.6% | -44.1% | -38.6% | -43.5% | -29.2%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 11.2% | 6.8% | -4.5% | -6.9% | 8.3% | -4.8% | 2.0% | -15.5% | -8.7% | -2.6%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -26.4% | -30.7% | -13.2% | -36.0% | -33.1% | -30.3% | -35.0% | -29.2% | -29.9% | -19.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -45.3% | -41.2% | -55.5% | -30.5% | -25.3% | -64.1% | -43.8% | -52.8% | -40.2% | -29.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.7% | -0.3% | -0.6% | 0.5% | 0.7% | -1.4% | -0.4% | -0.7% | 0.4% | 1.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.1% | -9.2% | -8.1% | -4.4% | -4.5% | -18.7% | -9.4% | -8.3% | -4.6% | -4.4%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -58.9% | -29.8% | -19.9% | -12.2% | -9.5% | -58.9% | -30.4% | -20.4% | -12.6% | -9.7%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 4.4% | 1.8% | 1.7% | -4.9% | -1.3% | 2.3% | -2.4% | -1.0% | -1.8% | -2.0%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -27.6% | -26.3% | -11.6% | -10.3% | -10.2% | -31.3% | -27.2% | -16.3% | -14.2% | -13.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -56.1% | -41.0% | -33.1% | -24.8% | -26.6% | -57.4% | -41.3% | -34.4% | -29.3% | -30.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.2% | -3.4% | -2.9% | 1.3% | 1.1% | 8.2% | -2.1% | -0.4% | -0.1% | 0.2%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -39.0% | -21.6% | -19.8% | -17.6% | -16.0% | -40.6% | -29.1% | -22.5% | -22.3% | -18.9%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -55.9% | -48.1% | -38.9% | -36.1% | -31.6% | -58.1% | -44.0% | -39.1% | -36.6% | -32.0%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 12.3% | 6.9% | 6.4% | -1.5% | -4.2% | 3.4% | -0.6% | -1.1% | 4.0% | -1.8%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -48.0% | -35.7% | -26.6% | -21.2% | -21.9% | -44.1% | -30.8% | -33.0% | -28.8% | -19.7%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -62.0% | -45.0% | -36.2% | -35.7% | -40.1% | -58.5% | -44.7% | -44.9% | -36.3% | -39.2%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.3% | -0.8% | 0.8% | 0.4% | -0.5% | 0.4% | -0.9% | 0.9% | 0.5% | -0.6%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -19.8% | -10.8% | -7.3% | -5.4% | -4.5% | -20.3% | -11.3% | -7.7% | -5.7% | -4.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -55.0% | -28.6% | -19.3% | -13.0% | -10.4% | -55.2% | -29.2% | -19.6% | -13.3% | -10.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.5% | 1.8% | 1.0% | 0.3% | 1.7% | 0.1% | -0.4% | 1.2% | 0.0% | 0.6%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -27.6% | -22.1% | -16.4% | -10.2% | -9.5% | -30.7% | -23.7% | -19.4% | -15.7% | -14.0%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -58.6% | -42.8% | -33.0% | -28.5% | -22.2% | -58.4% | -42.8% | -34.5% | -30.3% | -26.1%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.0% | -2.5% | -0.5% | -1.1% | 1.3% | 0.9% | -0.7% | -0.9% | 0.6% | 0.2%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -36.4% | -25.6% | -18.4% | -15.7% | -15.6% | -36.6% | -29.0% | -20.2% | -22.6% | -18.6%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -50.8% | -43.3% | -37.6% | -29.5% | -28.4% | -52.8% | -44.3% | -39.0% | -33.3% | -31.5%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -2.9% | 7.0% | 0.1% | 3.4% | 3.7% | -0.3% | 3.5% | -0.1% | -0.9% | 1.4%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -36.8% | -35.3% | -28.5% | -25.4% | -20.4% | -37.5% | -34.6% | -29.1% | -23.9% | -23.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -53.6% | -47.0% | -40.9% | -37.9% | -30.7% | -54.6% | -48.9% | -41.0% | -38.5% | -31.9%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.6% | 0.2% | -0.4% | 0.2% | 0.0% | 0.7% | 0.3% | -0.4% | 0.2% | 0.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -17.2% | -10.4% | -6.7% | -5.3% | -4.2% | -17.9% | -10.9% | -6.9% | -5.5% | -4.4%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -49.9% | -28.4% | -18.3% | -13.3% | -9.6% | -50.3% | -29.0% | -18.7% | -13.6% | -9.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.3% | -0.5% | -0.8% | 0.1% | 0.9% | 0.0% | -0.9% | -0.7% | -0.2% | 1.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -29.8% | -20.5% | -14.3% | -10.7% | -8.4% | -31.4% | -22.8% | -18.0% | -14.9% | -12.3%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -54.3% | -40.6% | -30.5% | -24.6% | -21.0% | -54.5% | -41.8% | -33.5% | -28.2% | -24.9%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.7% | 2.2% | 0.8% | 0.1% | 0.9% | 1.8% | 0.7% | -0.9% | -0.8% | -0.9%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -32.1% | -28.2% | -21.5% | -18.9% | -13.6% | -34.3% | -29.3% | -24.2% | -21.7% | -17.6%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -57.2% | -46.1% | -37.8% | -29.5% | -29.1% | -57.6% | -45.9% | -39.4% | -33.2% | -31.3%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.6% | 2.3% | 0.0% | 1.9% | 1.6% | -1.5% | 0.0% | -0.4% | -1.4% | 1.1%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -36.8% | -34.3% | -24.7% | -22.0% | -20.6% | -37.5% | -34.6% | -26.5% | -23.0% | -22.2%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -57.1% | -46.4% | -44.6% | -38.4% | -34.6% | -58.1% | -47.7% | -42.6% | -37.7% | -34.4%

Table E31 Relative bias in the estimated slope, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.8% | -1.6% | 2.8% | -4.9% | -2.4% | 0.6% | -1.9% | 2.0% | -5.3% | -2.8%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -15.6% | -11.7% | -11.4% | -4.3% | -0.9% | -16.1% | -12.8% | -10.9% | -5.9% | -2.6%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -30.2% | -19.9% | -11.3% | -7.3% | -9.0% | -29.3% | -19.8% | -13.3% | -7.8% | -8.5%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -4.0% | -4.1% | 2.4% | -7.3% | -2.2% | -5.9% | 3.3% | 4.6% | -9.5% | 3.0%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -23.5% | -6.4% | -18.6% | -15.7% | -0.3% | -25.8% | -1.0% | -13.1% | -16.3% | -9.7%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -32.2% | -30.1% | -16.2% | -33.8% | -13.5% | -25.2% | -24.5% | -13.0% | -27.9% | -11.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -8.7% | 32.3% | -4.1% | 8.9% | 1.8% | -8.0% | 6.0% | -1.4% | 6.7% | 5.9%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -38.9% | -8.0% | -18.7% | -9.4% | -9.6% | -25.8% | -19.4% | -20.4% | -12.7% | -13.8%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -29.9% | -13.6% | -14.7% | -34.4% | -4.4% | -37.3% | -18.7% | -22.4% | -36.2% | -22.5%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -2.6% | 33.0% | 10.5% | -6.3% | -0.6% | -17.2% | 0.3% | -5.6% | -3.4% | 8.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -2.5% | -19.3% | -27.2% | -37.5% | -11.4% | -24.0% | -24.1% | -26.0% | -27.3% | 6.0%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -59.7% | -33.3% | -34.4% | -22.0% | -8.7% | -20.1% | -43.4% | -34.0% | -23.1% | 4.0%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -2.0% | 3.9% | 2.0% | -1.0% | -1.9% | -2.1% | 3.8% | 2.0% | -1.2% | -1.8%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -7.7% | -7.4% | -4.9% | -3.1% | -6.0% | -8.7% | -8.7% | -5.7% | -3.6% | -6.2%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -39.1% | -21.0% | -17.1% | -10.3% | -7.5% | -38.1% | -20.1% | -18.7% | -10.3% | -8.1%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -9.1% | -6.1% | 0.8% | 2.0% | -1.6% | -6.3% | -9.0% | 1.6% | -1.4% | -1.1%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -16.1% | -22.8% | -15.1% | -11.1% | -6.7% | -20.2% | -23.9% | -14.9% | -10.3% | -8.7%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -34.1% | -29.4% | -23.7% | -22.0% | -14.2% | -32.5% | -29.6% | -22.7% | -18.5% | -15.5%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.2% | 9.7% | 12.3% | 0.6% | -3.9% | 1.6% | -1.2% | 0.0% | -0.2% | -2.8%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -27.3% | -15.6% | -14.6% | -15.2% | 8.3% | -32.8% | -9.7% | -23.8% | -15.3% | 0.6%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -44.5% | -34.9% | -17.1% | -44.8% | -22.8% | -37.9% | -21.7% | -29.8% | -26.3% | -13.8%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.4% | 2.4% | -2.9% | -8.7% | 7.0% | -7.7% | -1.5% | -19.4% | -14.4% | -5.2%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -16.3% | -23.3% | -8.1% | -36.7% | -28.7% | -6.3% | -26.0% | -24.1% | -22.8% | -11.0%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -35.0% | -30.6% | -43.1% | -19.2% | -22.9% | -54.8% | -21.1% | -26.9% | -24.9% | -23.7%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.8% | -0.4% | -0.5% | 0.6% | 0.7% | -1.4% | -0.5% | -0.7% | 0.5% | 0.9%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.6% | -7.1% | -6.2% | -3.5% | -4.0% | -15.5% | -7.1% | -6.7% | -3.9% | -4.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -36.1% | -18.8% | -14.3% | -9.4% | -7.0% | -35.1% | -18.7% | -14.7% | -10.3% | -7.8%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 4.6% | 1.6% | 1.5% | -4.8% | -1.2% | 2.6% | -3.1% | -1.6% | -1.9% | -2.5%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -19.3% | -18.9% | -8.1% | -7.7% | -8.6% | -19.3% | -16.3% | -10.9% | -9.1% | -9.8%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -40.9% | -26.3% | -23.6% | -16.2% | -20.2% | -40.2% | -22.1% | -20.1% | -16.7% | -20.7%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 4.1% | -4.1% | -3.3% | 0.6% | 0.6% | 8.8% | -3.6% | -0.1% | -1.3% | 0.0%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -30.2% | -16.1% | -14.4% | -13.6% | -11.4% | -28.1% | -18.9% | -16.0% | -14.3% | -12.8%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -45.0% | -36.4% | -27.3% | -25.9% | -23.5% | -43.0% | -25.6% | -23.6% | -22.8% | -20.2%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 12.3% | 4.8% | 6.9% | -0.3% | -2.9% | 3.9% | -2.2% | -4.1% | 5.7% | -2.4%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -41.5% | -26.4% | -20.3% | -13.6% | -16.9% | -34.5% | -17.1% | -22.9% | -19.8% | -11.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -48.9% | -33.1% | -25.3% | -24.4% | -32.6% | -37.9% | -27.7% | -26.3% | -20.9% | -25.5%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.3% | -0.7% | 0.7% | 0.5% | -0.5% | 0.3% | -0.8% | 0.9% | 0.5% | -0.6%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.4% | -8.8% | -6.5% | -5.1% | -4.1% | -14.5% | -9.4% | -7.4% | -5.7% | -4.6%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -33.3% | -18.1% | -14.0% | -10.2% | -8.8% | -32.3% | -18.0% | -14.5% | -11.1% | -9.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.6% | 2.0% | 0.9% | 0.3% | 1.7% | -0.8% | 0.2% | 1.1% | 0.0% | 0.6%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -20.0% | -16.7% | -12.6% | -8.5% | -7.6% | -20.6% | -16.4% | -13.9% | -13.0% | -11.1%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -41.9% | -30.5% | -22.6% | -20.6% | -16.3% | -38.1% | -26.3% | -20.3% | -19.2% | -17.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.5% | -1.8% | -0.1% | -1.5% | 1.6% | 1.1% | 0.3% | -0.4% | 0.0% | 0.4%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -26.8% | -18.8% | -12.6% | -12.5% | -13.0% | -23.6% | -19.6% | -13.7% | -17.6% | -14.3%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -36.6% | -29.0% | -26.3% | -19.2% | -19.8% | -33.9% | -25.0% | -22.5% | -18.7% | -19.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -1.6% | 7.1% | 0.6% | 3.9% | 3.7% | -1.0% | 3.3% | 0.0% | -1.6% | 1.3%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -24.9% | -28.4% | -20.6% | -18.2% | -16.3% | -22.6% | -24.1% | -18.2% | -13.2% | -16.8%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -40.7% | -33.8% | -28.3% | -25.5% | -21.5% | -36.7% | -30.7% | -24.8% | -22.5% | -17.2%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.6% | 0.3% | -0.4% | 0.3% | 0.0% | 0.7% | 0.5% | -0.4% | 0.3% | 0.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -12.6% | -8.6% | -5.8% | -4.7% | -3.9% | -13.1% | -9.2% | -6.2% | -5.2% | -4.4%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -29.7% | -19.4% | -13.8% | -11.0% | -8.3% | -28.8% | -19.5% | -14.4% | -11.6% | -9.0%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.3% | -0.5% | -0.8% | 0.1% | 0.7% | 0.0% | -0.9% | -0.6% | -0.1% | 1.2%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -22.4% | -15.8% | -11.6% | -8.4% | -7.3% | -21.7% | -16.1% | -13.5% | -11.4% | -10.1%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -38.1% | -28.3% | -22.1% | -17.6% | -15.9% | -35.3% | -26.0% | -21.8% | -18.2% | -17.2%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.4% | 2.0% | 0.6% | 0.0% | 0.7% | 1.4% | 0.6% | -0.8% | -1.1% | -1.0%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -23.9% | -22.1% | -16.1% | -14.7% | -10.1% | -23.0% | -20.7% | -16.5% | -15.0% | -11.7%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -43.9% | -32.9% | -27.3% | -21.0% | -20.9% | -40.1% | -27.8% | -23.6% | -21.0% | -20.0%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -0.4% | 2.9% | 0.4% | 1.8% | 1.3% | -2.6% | 0.0% | -0.6% | -2.0% | 0.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -28.4% | -26.9% | -19.0% | -16.4% | -15.1% | -25.3% | -24.6% | -17.2% | -14.8% | -14.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -44.2% | -33.3% | -33.6% | -29.2% | -25.3% | -40.6% | -30.3% | -26.6% | -23.6% | -21.2%

Table E32 Relative bias of imputed studies, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Fixed Effects in the Final Model Number of Studies | | | | | Random Effects in the Final Model Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65 | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.5% | -3.2% | 3.3% | -4.7% | -1.9% | -1.7% | -3.4% | 2.6% | -5.4% | -2.1%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | -18.1% | -10.7% | -11.3% | -3.3% | -1.3% | -19.2% | -12.3% | -10.9% | -4.7% | -2.7%
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | -33.2% | -22.4% | -11.8% | -8.7% | -9.2% | -32.5% | -21.8% | -13.7% | -9.3% | -9.0%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -8.4% | -1.5% | 1.9% | -8.6% | -2.8% | -8.8% | 3.2% | 6.7% | -10.7% | 1.5%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -27.3% | -7.6% | -20.4% | -17.5% | -0.9% | -29.7% | -1.6% | -15.5% | -18.1% | -9.8%
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -37.7% | -30.7% | -17.7% | -28.9% | -17.9% | -29.1% | -24.9% | -14.4% | -26.0% | -16.9%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -11.3% | 29.4% | 3.5% | 4.6% | 6.0% | -8.5% | 7.2% | 5.7% | 3.9% | 13.6%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -34.4% | -14.2% | -17.8% | -8.1% | -10.4% | -23.4% | -19.4% | -19.0% | -14.0% | -13.2%
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -35.5% | -15.9% | -17.4% | -34.8% | -6.9% | -40.0% | -22.0% | -24.2% | -35.3% | -23.8%
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -20.5% | 37.9% | 16.4% | -4.9% | -4.0% | -32.9% | 2.5% | 3.6% | 2.5% | 8.2%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 0.3% | -26.7% | -32.7% | -36.5% | -10.1% | -27.2% | -32.7% | -29.2% | -32.9% | 4.8%
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -66.1% | -44.3% | -41.4% | -30.4% | -12.9% | -27.2% | -54.7% | -40.0% | -32.7% | 1.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | -0.7% | 3.8% | 1.7% | -0.9% | -2.1% | -0.8% | 4.0% | 1.7% | -1.0% | -1.5%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | -8.6% | -8.0% | -4.4% | -3.4% | -6.3% | -8.8% | -9.3% | -5.0% | -3.9% | -6.6%
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | -40.6% | -22.2% | -17.8% | -11.4% | -8.3% | -39.6% | -21.3% | -19.8% | -11.5% | -9.0%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -9.2% | -7.9% | 0.7% | 0.4% | 1.2% | -8.7% | -10.4% | 1.8% | -4.1% | 0.8%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -17.9% | -22.6% | -14.6% | -13.0% | -7.0% | -23.2% | -22.7% | -14.6% | -13.6% | -10.0%
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -40.8% | -30.8% | -27.2% | -24.5% | -14.3% | -38.5% | -32.5% | -26.8% | -21.3% | -15.7%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | -0.5% | 8.8% | 9.2% | -0.4% | -4.2% | 1.8% | -1.3% | -0.4% | 0.6% | -4.0%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -22.8% | -17.0% | -14.6% | -14.3% | 7.8% | -30.5% | -12.6% | -22.2% | -14.2% | -0.5%
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -48.8% | -41.5% | -19.0% | -48.6% | -25.9% | -41.1% | -28.8% | -30.4% | -28.8% | -16.4%
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.5% | 2.1% | -5.2% | -10.7% | 4.0% | -6.3% | -5.1% | -21.1% | -14.5% | -11.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -17.2% | -28.7% | -13.2% | -37.4% | -31.4% | -7.3% | -27.7% | -31.4% | -25.0% | -12.8%
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -41.4% | -31.2% | -42.6% | -27.1% | -22.5% | -59.8% | -26.8% | -28.1% | -31.2% | -22.8%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | -1.8% | -0.5% | -0.8% | 0.5% | 0.6% | -1.3% | -0.3% | -1.1% | 0.4% | 1.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | -14.8% | -7.3% | -6.6% | -3.8% | -4.0% | -15.7% | -7.4% | -7.3% | -4.3% | -4.0%
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | -38.5% | -20.8% | -14.8% | -10.0% | -7.6% | -37.2% | -20.7% | -15.3% | -10.9% | -8.4%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 4.3% | 1.8% | 1.3% | -4.8% | -1.4% | 2.1% | -3.8% | -2.2% | -1.9% | -2.3%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -21.3% | -20.2% | -8.8% | -8.9% | -8.9% | -21.8% | -18.1% | -11.9% | -10.2% | -10.4%
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -41.4% | -28.9% | -25.0% | -17.2% | -20.4% | -40.4% | -25.4% | -22.1% | -17.4% | -20.9%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.8% | -5.2% | -3.8% | 1.5% | 0.6% | 5.7% | -4.3% | -0.5% | -0.5% | -0.5%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -32.0% | -16.5% | -14.3% | -15.9% | -11.9% | -29.1% | -21.0% | -16.0% | -16.7% | -13.0%
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -47.2% | -38.4% | -30.4% | -26.9% | -24.9% | -45.8% | -29.4% | -26.7% | -24.5% | -22.5%
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 13.2% | 4.1% | 5.7% | 0.0% | -5.5% | 4.2% | -2.8% | -2.5% | 5.6% | -4.3%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -43.5% | -30.5% | -23.5% | -14.2% | -17.6% | -35.6% | -18.8% | -24.2% | -20.3% | -13.6%
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -53.0% | -34.0% | -28.4% | -27.5% | -35.3% | -43.1% | -26.0% | -30.6% | -23.6% | -29.0%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.3% | -0.8% | 0.9% | 0.5% | -0.6% | 0.4% | -0.9% | 1.1% | 0.5% | -0.8%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | -15.1% | -9.3% | -6.5% | -5.0% | -4.1% | -15.1% | -9.9% | -7.4% | -5.6% | -4.7%
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | -35.3% | -19.7% | -14.8% | -10.3% | -8.8% | -33.9% | -19.5% | -15.3% | -11.1% | -9.6%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | -0.3% | 1.9% | 0.9% | 0.4% | 1.8% | 0.0% | -0.5% | 1.2% | 0.1% | 0.8%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -21.4% | -17.6% | -12.9% | -9.0% | -7.7% | -21.9% | -17.2% | -13.9% | -13.3% | -11.3%
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -44.2% | -32.2% | -24.5% | -21.9% | -17.4% | -40.6% | -28.2% | -22.1% | -20.4% | -18.3%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 3.8% | -2.3% | 0.5% | -0.9% | 1.4% | 1.9% | 0.2% | -0.4% | 0.3% | 0.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -28.8% | -19.4% | -13.2% | -13.2% | -12.9% | -25.8% | -20.8% | -13.7% | -17.8% | -14.1%
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -39.0% | -32.8% | -28.4% | -21.5% | -21.7% | -37.0% | -29.0% | -24.8% | -21.3% | -21.8%
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 0.0% | 6.9% | 2.0% | 5.7% | 2.9% | 2.3% | 1.4% | 0.3% | 0.6% | 0.9%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -27.2% | -29.7% | -20.6% | -20.8% | -16.4% | -25.0% | -25.5% | -19.1% | -16.2% | -17.6%
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -43.7% | -36.7% | -31.2% | -28.1% | -23.4% | -39.1% | -34.4% | -26.9% | -25.2% | -20.2%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.8% | 0.3% | -0.4% | 0.3% | 0.1% | 0.9% | 0.5% | -0.4% | 0.3% | 0.1%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | -12.8% | -8.5% | -5.7% | -4.6% | -4.0% | -13.2% | -9.0% | -6.1% | -5.1% | -4.5%
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | -31.0% | -19.7% | -13.8% | -10.8% | -8.0% | -29.9% | -19.7% | -14.3% | -11.4% | -8.7%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.0% | -0.3% | -0.8% | 0.3% | 0.8% | -0.5% | -0.9% | -0.8% | 0.0% | 1.0%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | -22.9% | -16.1% | -11.5% | -8.7% | -7.4% | -21.8% | -16.5% | -13.4% | -11.5% | -9.9%
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | -40.0% | -29.7% | -22.9% | -18.5% | -16.5% | -36.9% | -27.3% | -22.6% | -18.9% | -17.6%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.8% | 1.6% | 1.0% | -0.2% | 1.4% | 1.8% | 0.8% | -1.0% | -1.5% | -0.7%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | -24.7% | -22.7% | -16.6% | -14.7% | -10.1% | -23.7% | -21.3% | -16.8% | -15.0% | -11.9%
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | -45.9% | -35.6% | -28.7% | -23.0% | -22.6% | -42.3% | -30.6% | -25.9% | -22.9% | -21.6%
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | -1.0% | 3.9% | -0.3% | 1.5% | 0.3% | -3.2% | 1.3% | -0.8% | -2.4% | 0.6%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | -28.8% | -27.4% | -19.3% | -16.9% | -15.1% | -25.4% | -24.5% | -18.0% | -15.7% | -14.5%
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | -47.4% | -36.4% | -36.0% | -30.9% | -26.0% | -43.8% | -33.1% | -29.7% | -26.0% | -22.8%

Table E33 Mean number of imputed studies, with R studies imputed (from 2-dimensional algorithmic variant)

R Missing Studies Imputed | | | | Number of Studies
R Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.507 | 0.518 | 0.527 | 0.491 | 0.476
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.066 | 4.573 | 4.846 | 4.810 | 4.904
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 5.158 | 7.959 | 8.865 | 9.354 | 9.481
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.730 | 0.696 | 0.700 | 0.654 | 0.661
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.444 | 4.451 | 4.805 | 5.186 | 5.349
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.377 | 5.647 | 7.010 | 8.310 | 8.844
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.941 | 1.000 | 0.967 | 0.941 | 0.885
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.884 | 4.155 | 4.722 | 5.116 | 5.310
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.628 | 4.692 | 5.922 | 7.086 | 8.054
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.233 | 1.415 | 1.284 | 1.308 | 1.233
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.571 | 3.544 | 4.334 | 5.028 | 5.170
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.140 | 3.865 | 5.086 | 6.110 | 7.187
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.494 | 0.507 | 0.497 | 0.508 | 0.485
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.200 | 4.597 | 4.808 | 4.879 | 4.820
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 5.192 | 7.932 | 8.857 | 9.184 | 9.371
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.709 | 0.678 | 0.693 | 0.653 | 0.631
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.466 | 4.475 | 4.895 | 5.257 | 5.180
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.401 | 5.472 | 7.215 | 8.291 | 8.880
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.012 | 0.940 | 0.973 | 0.913 | 0.873
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.959 | 4.110 | 4.545 | 4.935 | 5.247
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.617 | 4.473 | 6.085 | 7.254 | 7.841
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.154 | 1.305 | 1.291 | 1.319 | 1.236
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.592 | 3.654 | 4.381 | 4.775 | 5.206
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.076 | 3.819 | 5.132 | 6.164 | 7.062
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.522 | 0.499 | 0.487 | 0.476 | 0.496
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 4.059 | 4.513 | 4.567 | 4.618 | 4.661
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 5.008 | 7.503 | 8.497 | 8.887 | 8.911
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.731 | 0.695 | 0.672 | 0.661 | 0.621
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.446 | 4.334 | 4.763 | 5.059 | 5.263
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.357 | 5.488 | 7.095 | 8.061 | 8.667
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.935 | 0.970 | 0.967 | 0.925 | 0.929
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.874 | 3.978 | 4.456 | 5.040 | 5.185
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.652 | 4.445 | 6.031 | 7.010 | 8.062
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.202 | 1.307 | 1.310 | 1.193 | 1.231
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.467 | 3.572 | 4.228 | 4.965 | 5.209
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.166 | 3.786 | 5.134 | 6.089 | 7.148
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.533 | 0.490 | 0.528 | 0.514 | 0.481
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.692 | 4.071 | 4.094 | 4.046 | 4.172
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.628 | 6.768 | 7.464 | 7.679 | 7.707
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.736 | 0.722 | 0.649 | 0.690 | 0.639
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.228 | 4.102 | 4.474 | 4.685 | 4.760
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.267 | 5.440 | 6.661 | 7.611 | 8.087
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.999 | 0.966 | 0.952 | 0.899 | 0.811
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.813 | 3.840 | 4.478 | 4.734 | 5.066
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.659 | 4.420 | 5.779 | 6.866 | 7.741
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.109 | 1.347 | 1.217 | 1.220 | 1.299
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.537 | 3.585 | 4.166 | 4.833 | 5.099
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.138 | 3.765 | 5.101 | 6.283 | 7.069
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 0.524 | 0.533 | 0.506 | 0.524 | 0.506
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.232 | 3.596 | 3.631 | 3.636 | 3.676
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.166 | 5.745 | 6.060 | 6.157 | 6.361
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 0.733 | 0.685 | 0.669 | 0.673 | 0.645
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.137 | 3.823 | 4.307 | 4.168 | 4.454
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 3.105 | 5.066 | 6.150 | 6.777 | 7.250
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 0.984 | 0.979 | 1.004 | 0.924 | 0.912
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.767 | 3.736 | 4.318 | 4.619 | 4.771
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.620 | 4.383 | 5.659 | 6.622 | 7.100
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 1.156 | 1.297 | 1.391 | 1.339 | 1.209
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.454 | 3.515 | 4.207 | 4.480 | 5.092
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 2.181 | 3.820 | 5.134 | 6.196 | 6.982

Table E34 Mean number of imputed studies, with L studies imputed (from 2-dimensional algorithmic variant)

L Missing Studies Imputed | | | | Number of Studies
L Missing Studies Imputed | | | | 25 | 35 | 45 | 55 | 65
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.216 | 1.382 | 1.614 | 1.760 | 1.907
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.618 | 4.233 | 4.700 | 4.867 | 5.137
β_1_ = 0.049 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.137 | 6.227 | 7.300 | 8.087 | 8.422
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.715 | 2.064 | 2.522 | 2.938 | 3.333
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.003 | 4.028 | 4.742 | 5.529 | 6.038
β_1_ = 0.049 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.781 | 4.364 | 5.581 | 6.793 | 7.700
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.065 | 2.647 | 3.418 | 3.723 | 4.473
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.558 | 3.766 | 4.574 | 5.558 | 6.281
β_1_ = 0.049 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.186 | 3.559 | 4.580 | 5.656 | 6.729
β_1_ = 0.049 | | Number of Missing Studies
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.354 | 3.281 | 3.982 | 4.722 | 5.315
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.297 | 3.221 | 4.226 | 5.188 | 6.042
β_1_ = 0.049 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 1.783 | 2.921 | 3.829 | 4.731 | 5.760
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.171 | 1.377 | 1.616 | 1.699 | 1.831
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.693 | 4.288 | 4.744 | 4.894 | 4.995
β_1_ = 0.074 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.203 | 6.268 | 7.392 | 8.053 | 8.426
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.642 | 2.055 | 2.443 | 2.914 | 3.218
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.072 | 4.157 | 4.838 | 5.581 | 6.062
β_1_ = 0.074 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.740 | 4.263 | 5.714 | 6.827 | 7.800
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.049 | 2.655 | 3.323 | 3.712 | 4.493
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.653 | 3.735 | 4.539 | 5.301 | 6.242
β_1_ = 0.074 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.199 | 3.443 | 4.715 | 5.774 | 6.600
β_1_ = 0.074 | | Number of Missing Studies
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.286 | 3.247 | 3.871 | 4.698 | 5.411
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.310 | 3.362 | 4.204 | 5.046 | 5.945
β_1_ = 0.074 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 1.725 | 2.784 | 3.878 | 4.917 | 5.639
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.192 | 1.427 | 1.562 | 1.758 | 1.851
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.623 | 4.331 | 4.634 | 4.784 | 5.099
β_1_ = 0.148 | τ^2^ = 0 | Number of Missing Studies | 10 | 4.107 | 6.148 | 7.276 | 7.999 | 8.386
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.702 | 2.095 | 2.549 | 2.902 | 3.291
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 3.100 | 3.996 | 4.877 | 5.539 | 6.182
β_1_ = 0.148 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.742 | 4.364 | 5.732 | 6.772 | 7.680
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 1.996 | 2.690 | 3.257 | 3.708 | 4.335
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.622 | 3.614 | 4.455 | 5.424 | 6.130
β_1_ = 0.148 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.182 | 3.429 | 4.740 | 5.594 | 6.907
β_1_ = 0.148 | | Number of Missing Studies
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.395 | 3.160 | 3.940 | 4.731 | 5.447
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.228 | 3.315 | 4.103 | 5.303 | 6.027
β_1_ = 0.148 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 1.759 | 2.857 | 3.943 | 4.958 | 5.892
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.207 | 1.353 | 1.604 | 1.836 | 1.941
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.518 | 4.188 | 4.448 | 4.786 | 4.948
β_1_ = 0.296 | τ^2^ = 0 | Number of Missing Studies | 10 | 3.883 | 5.907 | 7.115 | 7.760 | 8.250
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.713 | 2.115 | 2.560 | 2.940 | 3.310
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 2.970 | 3.986 | 4.741 | 5.452 | 5.968
β_1_ = 0.296 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.723 | 4.382 | 5.586 | 6.659 | 7.487
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.070 | 2.723 | 3.197 | 3.839 | 4.289
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.547 | 3.619 | 4.535 | 5.369 | 6.203
β_1_ = 0.296 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.206 | 3.429 | 4.531 | 5.621 | 6.761
β_1_ = 0.296 | | Number of Missing Studies
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.340 | 3.214 | 3.889 | 4.685 | 5.571
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.280 | 3.307 | 4.204 | 5.083 | 5.959
β_1_ = 0.296 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 1.767 | 2.876 | 3.823 | 4.972 | 5.864
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 0 | 1.227 | 1.449 | 1.593 | 1.757 | 1.863
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 5 | 3.425 | 4.109 | 4.464 | 4.742 | 4.916
β_1_ = 0.444 | τ^2^ = 0 | Number of Missing Studies | 10 | 3.661 | 5.514 | 6.534 | 7.303 | 7.950
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 0 | 1.687 | 2.167 | 2.563 | 2.829 | 3.231
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 5 | 2.952 | 3.849 | 4.847 | 5.223 | 6.039
β_1_ = 0.444 | τ^2^ = 0.049 | Number of Missing Studies | 10 | 2.665 | 4.238 | 5.398 | 6.477 | 7.352
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 0 | 2.070 | 2.660 | 3.291 | 3.806 | 4.419
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 5 | 2.598 | 3.597 | 4.575 | 5.426 | 6.251
β_1_ = 0.444 | τ^2^ = 0.148 | Number of Missing Studies | 10 | 2.215 | 3.446 | 4.570 | 5.664 | 6.377
β_1_ = 0.444 | | Number of Missing Studies
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 0 | 2.279 | 3.090 | 4.170 | 5.047 | 5.466
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 5 | 2.233 | 3.302 | 4.225 | 4.889 | 6.069
β_1_ = 0.444 | τ^2^ = 0.444 | Number of Missing Studies | 10 | 1.813 | 2.957 | 3.957 | 4.919 | 5.947