# Output From Example

| METHODL | MODEL | PARAM | Estimate | St Error | Stat | P | Lower CI | Upper CI | CovBeta1 | CovBeta2
1 | OBSERVED | FIX | Intercept | 0.3494971 | 0.07918507 | 4.413674 | 1.016311e-05 | 0.1942972 | 0.5046970 | 0.006270276 | -0.006270276
2 | OBSERVED | FIX | Covariate | -0.3708776 | 0.08928915 | -4.153669 | 3.271863e-05 | -0.5458811 | -0.1958741 | -0.006270276 | 0.007972552
3 | OBSERVED | RAN | Intercept | 0.3494971 | 0.07918507 | 4.413674 | 1.016311e-05 | 0.1942972 | 0.5046970 | 0.006270276 | -0.006270276
4 | OBSERVED | RAN | Covariate | -0.3708776 | 0.08928915 | -4.153669 | 3.271863e-05 | -0.5458811 | -0.1958741 | -0.006270276 | 0.007972552
5 | OBSERVED | RAN | Tauˆ2 | 0.0000000 | NA | 16.786276 | 4.689346e-01 | NA | NA | NA | NA
6 | FILLED | FIX | Intercept | 0.3494971 | 0.07918507 | 4.413674 | 1.016311e-05 | 0.1942972 | 0.5046970 | 0.006270276 | -0.006270276
7 | FILLED | FIX | Covariate | -0.3708776 | 0.08928915 | -4.153669 | 3.271863e-05 | -0.5458811 | -0.1958741 | -0.006270276 | 0.007972552
8 | FILLED | RAN | Intercept | 0.3494971 | 0.07918507 | 4.413674 | 1.016311e-05 | 0.1942972 | 0.5046970 | 0.006270276 | -0.006270276
9 | FILLED | RAN | Covariate | -0.3708776 | 0.08928915 | -4.153669 | 3.271863e-05 | -0.5458811 | -0.1958741 | -0.006270276 | 0.007972552
10 | FILLED | RAN | Tau^2 | 0.0000000 | NA | 16.786276 | 4.689346e-01 | NA | NA | NA | NA
11 | <NA> | <NA? | L-hat | 0.0000000 | NA | NA | NA | NA | NA | NA | NA