# Program Documentation

## Trim and Fill for Meta-regression

### Description

trim.fill.regression is used to perform trim and fill in a metaregression, in which publication bias is assumed to have censored some study estimates.

### Usage

trim.fill.regression(theta.hat, s.e.theta, covariate,
		    k.estimator, t.f.mod, t.f.dim,
		    fill.range, level = 0.95)

### Arguments

theta.hat | A vector consisting of study effect estimates, on whichever scale estimates are assumed to be normally distributed (typically, log).
s.e.theta | A vector consisting of standard errors of study effect estimates.
covariate | A vector consisting of measured values of a variable assumed to be associated with effect estimate.
k.estimator | The formula used to estimate the number of missing studies; options include “R,” “L,” or “Q.”
t.f.mod | The model formulation for the iterative step of trim and fill; either “FIX” (fixed effects model) or “RAN” (random effects model).
t.f.dim | The dimension of the model that is fit during the iterative step of trim and fill; options include 1 or 2.
fill.range | The range over which covariate values are reflected during the fill phase of trim and fill; options include “MLE” (maximum likelihood), “MOM” (method of moments), or a user-supplied vector c(a, b), with a as the minimum and b as the maximum of the fill interval.
level | Level of statistical significance (to determine confidence interval width).

### Details

Currently, in its beta form, trim.fill.regression supports trim and fill in a metaregression with only one covariate. Use of multiple vectors in the covariate argument will result in an error.

The options for k.estimator include R = \gamma^star – 1, L = [4 * T_n – n * (n – 1)] / [2 * n – 1], and Q = n – ½ - sqrt[2 * n^2 – 4 * T_n + ¼], where \gammaˆstar and T_n are defined as in Duval (2000), and n is the number of observed studies. Note that Q may be undefined, in which case trim.fill.regression will return an error code dictating so. In simulation studies of the algorithm in meta.fit, R generally performed superiorly.

Like for trim and fill in a standard (one-dimensional) meta-analysis, “FIX” is highly recommended as the t.f.mod argument.

Simulation studies have generally suggested that t.f.dim = 1 is recommended, although this suggestion may depend some upon the assumed censoring mechanism. Note that if t.f.dim = 2, it is possible for the estimate of k to be equal to 1 during the iterative phase of trim and fill, in which case trim.fill.regression will return an error code dictating so, although this occurs rarely.

For fill.range, use of “MLE” corresponds to a fill interval [a, b] , where a is the minimum of covariate, and b is the maximum, while use of “MOM” corresponds to a fill interval [x-bar – sqrt[3] * s, x-bar + sqrt[3] * s], where x-bar is the mean of covariate, and s is its estimated standard deviation.

### Value

trim.fill.regression returns a matrix of analytical results, meta.fit, and four vectors of data, t.f.theta.hat, t.f.s.e.theta, t.f.covariate, t.f.fill.flag.

meta.fit consists an 11-by-11 matrix. The first set of five rows corresponds to a meta-regression analysis of the observed data, under both a fixed-effects and a random-effects model. The fifth row includes an estimate of \tauˆ2 (between-study variability) from the random-effects model, along with a test of its significance. The second set of five rows corresponds to a meta-regression analysis of observed and imputed data, after trim and fill has imputed missing studies, under both a fixed-effects and a random-effects model. The tenth row again includes an estimate of \tauˆ2 from the random-effects model, along with a test of its significance. The final row of meta.fit includes the estimate of k, with whichever estimator was requested by the user. Finally, the 10th and 11th columns of the matrix include the covariance matrix of the parameter estimates.

The vectors t.f.theta.hat, t.f.s.e.theta, and t.f.covariate are analogous to the user-supplied arguments theta.hat, s.e.theta, and covariate, but with imputed studies appended to the original vectors. The vector t.f.fill.flag is of identical length as t.f.theta.hat.It includes binary indicators of whether each value in t.f.theta.hat represents an observed study (0) or an imputed study (1).

### Examples

##### Example 1
example <- read.csv(“C:\\example.csv”, header = F)
trim.fill.regression(example[, 1], example[, 2], example[, 3],
		  “R”, “FIX”, 1,
		  c(0, 1))

##### Example 2

y <- c(  0.54, -0.32,  0.12, -0.06, -0.02,
	-0.18,  0.07,  0.18, -0.07, -0.06,
	 0.23, -0.14, -0.02,  0.27,  0.80,
	 1.18,  0.26,  0.30,  0.03)

sigma <- c(0.306957, 0.221297, 0.147462, 0.103098, 0.103264,
	   0.158934, 0.093603, 0.223096, 0.174151, 0.166704,
	   0.290517, 0.166871, 0.288682, 0.164595, 0.259808,
	   0.396813, 0.370659, 0.139452, 0.126246)

x <- c(0, 1, 1, 1, 1,
	1, 1, 0, 1, 1,
	1, 1, 0, 0, 0,
	0, 0, 0, 1)

trim.fill.regression(y, sigma, x,
		  “L”, “FIX”, 2,
		  “MLE”)

### References

Duval S, Tweedie R. A nonparametric “trim and fill” method of accounting for publication bias in meta-analysis. Journal of the American Statistical Association. 2000;95:89-98.