# Software Program Code

trim.fill.regression <- function (theta.hat, s.e.theta, covariate,
					k.estimator, t.f.mod, t.f.dim,
					fill.range, level = 0.95) {

dim.beta <- 2

n.obs.1 <- length(theta.hat)
n.obs.2 <- length(s.e.theta)
n.obs.3 <- length(covariate)

n.check <- 1 * (var(c(n.obs.1, n.obs.2, n.obs.3)) == 0)

if (n.check == 0) {
	return(“ERROR. Argument lengths are not equal.”)
}
if (n.check == 1) {
	n.obs <- n.obs.1

	estimate.obs <- matrix(
			cbind(theta.hat, s.e.theta),
			nrow = n.obs, ncol = 2
			)

	x.design.obs <- matrix(
			cbind(rep(1, n.obs), covariate),
			nrow = n.obs, ncol = 2
			)

	meta.fit <- data.frame(
			matrix(NA, 2 * (2 * dim.beta + 1) + 1, 11)
			)

	names(meta.fit)[1] <- “METHOD”
	names(meta.fit)[2] <- “MODEL”
	names(meta.fit)[3] <- “PARAM”

	names(meta.fit)[4] <- “Estimate”
	names(meta.fit)[5] <- “St Error”
	names(meta.fit)[6] <- “Stat”
	names(meta.fit)[7] <- “P”

	names(meta.fit)[8] <- “Lower CI”
	names(meta.fit)[9] <- “Upper CI”

	names(meta.fit)[10] <- “CovBeta1”
	names(meta.fit)[11] <- “CovBeta2”

	for (i in 1 : 2) {
		if (i == 1) {
			inv.v <- solve(
				diag(estimate.obs[, 2]ˆ2, n.obs, n.obs)
				)

		}
		if (i == 2) {
			inv.v.fix <- solve(
					diag(estimate.obs[, 2]ˆ2, n.obs, n.obs)
					)

			m.1.fix <- solve(
					t(x.design.obs) %*% inv.v.fix %*% x.design.obs
				)

			q.hat <- t(estimate.obs[, 1]) %*%
				(inv.v.fix -
				inv.v.fix %*% x.design.obs %*% m.1.fix %*% t(x.design.obs)
%*% inv.v.fix) %*%
				estimate.obs[, 1]

			d.f <- n.obs - dim.beta

			if (dim.beta == 1) {
				c.hat <- sum(diag(inv.v.fix)) -
					sum(m.1.fix %*% t(x.design.obs) %*%inv.v.fix %*%
inv.v.fix %*% x.design.obs)
			}
			if (dim.beta > 1) {
				c.hat <- sum(diag(inv.v.fix)) -
					sum(diag(m.1.fix %*% t(x.design.obs) %*% inv.v.fix
%*% inv.v.fix %*% x.design.obs))
			}

			tau.sq.hat <- max(0, (q.hat - d.f) / c.hat)

			inv.v <- solve(
				diag(estimate.obs[, 2]ˆ2 + tau.sq.hat, n.obs, n.obs)
				)
		}

		m.1 <- solve(
			t(x.design.obs) %*% inv.v %*% x.design.obs
			)
		m.2 <- t(x.design.obs) %*% inv.v %*% estimate.obs[, 1]

		if (i == 1) {
			beta.hat.1 <- m.1 %*% m.2

			beta.cov.1 <- m.1

			if (dim.beta == 1) beta.err.1 <- sqrt(m.1)
			if (dim.beta > 1) beta.err.1 <- sqrt(diag(m.1))

		}
		if (i == 2) {
			beta.hat.2 <- m.1 %*% m.2

			beta.cov.2 <- m.1

			if (dim.beta == 1) beta.err.2 <- sqrt(m.1)
			if (dim.beta > 1) beta.err.2 <- sqrt(diag(m.1))
		}
	}

	mark.1 <- (1 - 1) * (2 * dim.beta + 1) + (1 - 1) * (dim.beta) + 1
	mark.2 <- (1 - 1) * (2 * dim.beta + 1) + (1 - 1) * (dim.beta) + dim.beta
	mark.3 <- (1 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + 1
	mark.4 <- (1 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + dim.beta
	mark.5 <- (1 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + dim.beta + 1

	meta.fit[mark.1 : mark.5, 1] <- rep(“OBSERVED”, 2 * dim.beta + 1)
	meta.fit[mark.1 : mark.5, 2] <- c(rep(“FIX”, dim.beta), rep(“RAN”, dim.beta + 1))
	meta.fit[mark.1 : mark.5, 3] <- c(rep(c(“Intercept”, “Covariate”), 2), “Tauˆ2”)

	meta.fit[mark.1 : mark.2, 4 : 5] <- cbind(beta.hat.1, beta.err.1)
	meta.fit[mark.3 : mark.4, 4 : 5] <- cbind(beta.hat.2, beta.err.2)

	meta.fit[mark.1 : mark.4, 6] <- meta.fit[mark.1 : mark.4, 4] / meta.fit[mark.1 : mark.4, 5]
	meta.fit[mark.1 : mark.4, 7] <- 2 * (1 - pnorm(abs(meta.fit[mark.1 : mark.4, 6])))
	meta.fit[mark.1 : mark.4, 8] <- meta.fit[1 : 4, 4] + qnorm(0 + (1 - level) / 2) *
meta.fit[mark.1 : mark.4, 5]
	meta.fit[mark.1 : mark.4, 9] <- meta.fit[1 : 4, 4] + qnorm(1 - (1 - level) / 2) *
meta.fit[mark.1 : mark.4, 5]

	meta.fit[mark.1 : mark.2, 10 : 11] <- beta.cov.1
	meta.fit[mark.3 : mark.4, 10 : 11] <- beta.cov.2

	meta.fit[mark.5, 4] <- tau.sq.hat
	meta.fit[mark.5, 6] <- q.hat

	meta.fit[mark.5, 7] <- 1 - pchisq(q.hat, df = d.f)

	assign(“meta.fit”, meta.fit, env = .GlobalEnv)

	if (t.f.mod == “FIX”) {
		inv.v <- solve(
			diag(estimate.obs[, 2]ˆ2, n.obs, n.obs)
			)
	}
	if (t.f.mod == “RAN”) {
		inv.v.fix <- solve(
				diag(estimate.obs[, 2]ˆ2, n.obs, n.obs)
				)

		m.1.fix <- solve(
				t(x.design.obs[, 1 : t.f.dim]) %*% inv.v.fix %*% x.design.obs[, 1 :
t.f.dim]
			)

		q.hat <- t(estimate.obs[, 1]) %*%
			(inv.v.fix -
			inv.v.fix %*% x.design.obs[, 1 : t.f.dim] %*% m.1.fix %*%
t(x.design.obs[, 1 : t.f.dim]) %*% inv.v.fix) %*%
			estimate.obs[, 1]

		d.f <- n.obs - t.f.dim

		if (dim.beta == 1) {
			c.hat <- sum(diag(inv.v.fix)) -
				sum(m.1.fix %*% t(x.design.obs[, 1 : t.f.dim]) %*% inv.v.fix
%*% inv.v.fix %*% x.design.obs[, 1 : t.f.dim])
		}
		if (dim.beta > 1) {
			c.hat <- sum(diag(inv.v.fix)) -
				  sum(diag(m.1.fix %*% t(x.design.obs[, 1 : t.f.dim]) %*%
inv.v.fix %*% inv.v.fix %*% x.design.obs[, 1 : t.f.dim]))
		}

		tau.sq.hat <- max(0, (q.hat - d.f) / c.hat)

		inv.v <- solve(
			diag(estimate.obs[, 2]ˆ2 + tau.sq.hat, n.obs, n.obs)
			)
	}

	m.1 <- solve(
		t(x.design.obs[, 1 : t.f.dim]) %*% inv.v %*% x.design.obs[, 1 : t.f.dim]
		)
	m.2 <- t(x.design.obs[, 1 : t.f.dim]) %*% inv.v %*% estimate.obs[, 1]

	iter.beta.hat <- m.1 %*% m.2

	residual <- round(
			estimate.obs[, 1] - x.design.obs[, 1 : t.f.dim] %*% iter.beta.hat,
			digits = 12
			)

	sign.rank <- cbind(
			sign(residual),
			rank(residual, ties.method = “random”),
			rank(abs(residual), ties.method = “random”)
			)

	if (min(sign.rank[, 1]) == -1) gamma.star <- n.obs - max(sign.rank[sign.rank[, 1] == -1,
3])
	if (min(sign.rank[, 1]) == 0) gamma.star <- n.obs - sum(sign.rank[, 1] == 0)

	if (max(sign.rank[, 1]) == 0) T.n <- 0
	if (max(sign.rank[, 1]) == 1) T.n <- sum(sign.rank[sign.rank[, 1] == 1, 3])

	if (k.estimator == “R”) {
		n.miss.hat <- max(0, gamma.star - 1)
		delta.n.miss.hat <- n.miss.hat - 0

		if (n.miss.hat > (n.obs - t.f.dim)) {
			n.miss.hat <- NA
			delta.n.miss.hat <- 0

			return(“ERROR. Trimmed data is of insufficient rank.”)
		}
	}
	if (k.estimator == “L”) {
		n.miss.hat <- max(0, floor((4 * T.n - n.obs * (n.obs + 1)) / (2 * n.obs - 1) + 1/2))
		delta.n.miss.hat <- n.miss.hat - 0

		if (n.miss.hat > (n.obs - t.f.dim)) {
			n.miss.hat <- NA
			delta.n.miss.hat <- 0

			return(“ERROR. Trimmed data is of insufficient rank.”)
		}
	}
	if (k.estimator == “Q”) {
		if ((2 * n.obsˆ2 - 4 * T.n + 1/4) < 0) {
			n.miss.hat <- NA
			delta.n.miss.hat <- 0

			return(“ERROR. Q-hat cannot be calculated.”)
		}
		if ((2 * n.obsˆ2 - 4 * T.n + 1/4) >= 0) {
			n.miss.hat <- max(0, floor((n.obs - 1/2) - sqrt(2 * n.obsˆ2 - 4 * T.n + 1/4)
+ 1/2))
			delta.n.miss.hat <- n.miss.hat - 0

			if (n.miss.hat > (n.obs - t.f.dim)) {
				n.miss.hat <- NA
				delta.n.miss.hat <- 0

				return(“ERROR. Trimmed data is of insufficient rank.”)
			}
		}
	}

	step <- 1

	while ((delta.n.miss.hat != 0) & (step <= 100)) {
		lag.n.miss.hat <- n.miss.hat

		retain <- (1 : n.obs)[!(sign.rank[, 2] > (n.obs - lag.n.miss.hat))]

		x.design.sub <- matrix(
				x.design.obs[retain, 1 : t.f.dim],
				ncol = t.f.dim
				)
		estimate.sub <- matrix(
				estimate.obs[retain, ],
				ncol = 2
				)

		n.sub <- nrow(estimate.sub)

		x.rank.check <- 1 * (qr(x.design.sub)$rank == t.f.dim)

		if (x.rank.check == 0) {
			n.miss.hat <- NA
			delta.n.miss.hat <- 0
		}

		if (x.rank.check == 1) {
			if (t.f.mod == “FIX”) {
				inv.v <- solve(
					diag(estimate.sub[, 2]ˆ2, n.sub, n.sub)
					)
			}
			if (t.f.mod == “RAN”) {
				if (n.sub == 1) {
					tau.sq.hat <- 0
				}
				if (n.sub > 1) {
					inv.v.fix <- solve(
							diag(estimate.sub[, 2]ˆ2, n.sub, n.sub)
							)
				m.1.fix <- solve(
						t(x.design.sub) %*% inv.v.fix %*%
x.design.sub
					)

				q.hat <- t(estimate.sub[, 1]) %*%
					(inv.v.fix -
					inv.v.fix %*% x.design.sub %*% m.1.fix %*%
t(x.design.sub) %*% inv.v.fix) %*%
					estimate.sub[, 1]

				d.f <- n.sub - t.f.dim

				if (t.f.dim == 1) {
					c.hat <- sum(diag(inv.v.fix)) -
						sum(m.1.fix %*% t(x.design.sub) %*%
inv.v.fix %*% inv.v.fix %*% x.design.sub)
				}
				if (t.f.dim > 1) {
					c.hat <- sum(diag(inv.v.fix)) -
						sum(diag(m.1.fix %*% t(x.design.sub)
%*% inv.v.fix %*% inv.v.fix %*% x.design.sub))
				}

				tau.sq.hat <- max(0, (q.hat - d.f) / c.hat)
			}

			inv.v <- solve(
				diag(estimate.sub[, 2]ˆ2 + tau.sq.hat, n.sub, n.sub)
				)
		}

			m.1 <- solve(
					t(x.design.sub) %*% inv.v %*% x.design.sub
					)
			m.2 <- t(x.design.sub) %*% inv.v %*% estimate.sub[, 1]
			iter.beta.hat <- m.1 %*% m.2
		}

		residual <- round(
			estimate.obs[, 1] - x.design.obs[, 1 : t.f.dim] %*% iter.beta.hat,
			digits = 12
			)

		sign.rank <- cbind(
			sign(residual),
			rank(residual, ties.method = “random”),
			rank(abs(residual), ties.method = “random”)
			)

		if (min(sign.rank[, 1]) == -1) gamma.star <- n.obs - max(sign.rank[sign.rank[, 1]
== -1, 3])
		if (min(sign.rank[, 1]) == 0) gamma.star <- n.obs - sum(sign.rank[, 1] == 0)

		if (max(sign.rank[, 1]) == 0) T.n <- 0
		if (max(sign.rank[, 1]) == 1) T.n <- sum(sign.rank[sign.rank[, 1] == 1, 3])

		if (k.estimator == “R”) {
			n.miss.hat <- max(0, gamma.star - 1)
			delta.n.miss.hat <- n.miss.hat - lag.n.miss.hat

			if (n.miss.hat > (n.obs - t.f.dim)) {
				n.miss.hat <- NA
				delta.n.miss.hat <- 0

				return(“ERROR. Trimmed data is of insufficient rank.”)
			}
		}
		if (k.estimator == “L”) {
			n.miss.hat <- max(0, floor((4 * T.n - n.obs * (n.obs + 1)) / (2 * n.obs - 1) +
1/2))
			delta.n.miss.hat <- n.miss.hat - lag.n.miss.hat

			if (n.miss.hat > (n.obs - t.f.dim)) {
				n.miss.hat <- NA
				delta.n.miss.hat <- 0
				return(“ERROR. Trimmed data is of insufficient rank.”)
			}
		}
		if (k.estimator == “Q”) {
			if ((2 * n.obsˆ2 - 4 * T.n + 1/4) < 0) {
				n.miss.hat <- NA
				delta.n.miss.hat <- 0

				return(“ERROR. Q-hat cannot be calculated.”)
			}
			if ((2 * n.obsˆ2 - 4 * T.n + 1/4) >= 0) {
				n.miss.hat <- max(0, floor((n.obs - 1/2) - sqrt(2 * n.obsˆ2 - 4 * T.n
+ 1/4) + 1/2))
				delta.n.miss.hat <- n.miss.hat - lag.n.miss.hat

				if (n.miss.hat > (n.obs - t.f.dim)) {
					n.miss.hat <- NA
					delta.n.miss.hat <- 0

					return(“ERROR. Trimmed data is of insufficient rank.”)
				}
			}
		}

		step <- step + 1

		if (step == 100) {
			n.miss.hat <- NA
			delta.n.miss.hat <- 0

			if (k.estimator == “R”) {
				return(“ERROR. R-hat does not converge.”)
			}
			if (k.estimator == “L”) {
				return(“ERROR. L-hat does not converge.”)
			}
			if (k.estimator == “Q”) {
				return(“ERROR. Q-hat does not converge.”)
			}
		}
	}

	n.miss.check <- 1 * (is.na(n.miss.hat) == 0)

	if (n.miss.check == 1) {
		if (n.miss.hat == 0) {
			x.design.t.f.1 <- x.design.obs

			estimate.t.f.1 <- estimate.obs

			x.design.t.f <- rbind(x.design.t.f.1)
			estimate.t.f <- rbind(estimate.t.f.1)

			n.t.f <- nrow(estimate.t.f)
		}
		if (n.miss.hat > 0) {
			range.check <- 1 * (is.numeric(fill.range))

			if (range.check == 0) {
				if (fill.range == “MLE”) {
					mid.range <- mean(c(min(x.design.obs[, 2]),
max(x.design.obs[, 2])))
				}
				if (fill.range == “MOM”) {
					mid.range <- mean(x.design.obs[, 2])
				}
			}
			if (range.check == 1) {
				mid.range <- mean(c(fill.range[1], fill.range[2]))
			}

			x.design.t.f.1 <- x.design.obs
			x.design.t.f.2 <- matrix(
						cbind(
						rep(1, n.miss.hat),
						2 * mid.range - x.design.obs[(sign.rank[, 2] >
	(n.obs - n.miss.hat)), 2]
						),
						nrow = n.miss.hat, ncol = 2
						)

			estimate.t.f.1 <- estimate.obs
			estimate.t.f.2 <- cbind(
						x.design.t.f.2[, 1 : t.f.dim] %*% iter.beta.hat -
	residual[(sign.rank[, 2] > (n.obs - n.miss.hat)), ],
						estimate.obs[(sign.rank[, 2] > (n.obs - n.miss.hat)),
	2]
						)

			x.design.t.f <- rbind(x.design.t.f.1, x.design.t.f.2)
			estimate.t.f <- rbind(estimate.t.f.1, estimate.t.f.2)
			n.t.f <- nrow(estimate.t.f)
		}

		t.f.theta.hat <- estimate.t.f[, 1]
		t.f.s.e.theta <- estimate.t.f[, 2]
		t.f.covariate <- x.design.t.f[, 2]
		t.f.fill.flag <- c(rep(0, n.obs), rep(1, n.miss.hat))

		assign(“t.f.theta.hat”, t.f.theta.hat, env = .GlobalEnv)
		assign(“t.f.s.e.theta”, t.f.s.e.theta, env = .GlobalEnv)
		assign(“t.f.covariate”, t.f.covariate, env = .GlobalEnv)
		assign(“t.f.fill.flag”, t.f.fill.flag, env = .GlobalEnv)

		for (i in 1 : 2) {
			if (i == 1) {
				inv.v <- solve(
					diag(estimate.t.f[, 2]ˆ2, n.t.f, n.t.f)
					)
			}
			if (i == 2) {
				if (n.t.f == 1) {
					tau.sq.hat <- 0
				}
				if (n.t.f > 1) {
					inv.v.fix <- solve(
							diag(estimate.t.f[, 2]ˆ2, n.t.f, n.t.f)
							)

					m.1.fix <- solve(
							t(x.design.t.f) %*% inv.v.fix %*%
	x.design.t.f
						)

					q.hat <- t(estimate.t.f[, 1]) %*%
						(inv.v.fix - inv.v.fix %*% x.design.t.f %*%
	m.1.fix %*% t(x.design.t.f) %*% inv.v.fix) %*%
						estimate.t.f[, 1]

					d.f <- n.t.f - dim.beta

					if (dim.beta == 1) {
						c.hat <- sum(diag(inv.v.fix)) -
							 sum(m.1.fix %*% t(x.design.t.f) %*%
	inv.v.fix %*% inv.v.fix %*% x.design.t.f)
					}

					if (dim.beta > 1) {
						c.hat <- sum(diag(inv.v.fix)) -
							sum(diag(m.1.fix %*% t(x.design.t.f)
	%*% inv.v.fix %*% inv.v.fix %*% x.design.t.f))
					}

					tau.sq.hat <- max(0, (q.hat - d.f) / c.hat)
				}

				inv.v <- solve(
					diag(estimate.t.f[, 2]ˆ2 + tau.sq.hat, n.t.f, n.t.f)
					)
			}

			m.1 <- solve(
				t(x.design.t.f) %*% inv.v %*% x.design.t.f
				)
			m.2 <- t(x.design.t.f) %*% inv.v %*% estimate.t.f[, 1]

			if (i == 1) {
				beta.hat.1 <- m.1 %*% m.2

				beta.cov.1 <- m.1

				if (dim.beta == 1) beta.err.1 <- sqrt(m.1)
				if (dim.beta > 1) beta.err.1 <- sqrt(diag(m.1))
			}
			if (i == 2) {
				beta.hat.2 <- m.1 %*% m.2

				beta.cov.2 <- m.1

				if (dim.beta == 1) beta.err.2 <- sqrt(m.1)
				if (dim.beta > 1) beta.err.2 <- sqrt(diag(m.1))
			}
		}

		mark.1 <- (2 - 1) * (2 * dim.beta + 1) + (1 - 1) * (dim.beta) + 1
		mark.2 <- (2 - 1) * (2 * dim.beta + 1) + (1 - 1) * (dim.beta) + dim.beta
		mark.3 <- (2 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + 1
		mark.4 <- (2 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + dim.beta
		mark.5 <- (2 - 1) * (2 * dim.beta + 1) + (2 - 1) * (dim.beta) + dim.beta + 1

		meta.fit[mark.1 : mark.5, 1] <- rep(“FILLED”, 2 * dim.beta + 1)
		meta.fit[mark.1 : mark.5, 2] <- c(rep(“FIX”, dim.beta), rep(“RAN”, dim.beta + 1))
		meta.fit[mark.1 : mark.5, 3] <- c(rep(c(“Intercept”, “Covariate”), 2), “Tauˆ2”)
		meta.fit[mark.1 : mark.2, 4 : 5] <- cbind(beta.hat.1, beta.err.1)
		meta.fit[mark.3 : mark.4, 4 : 5] <- cbind(beta.hat.2, beta.err.2)

		meta.fit[mark.1 : mark.4, 6] <- meta.fit[mark.1 : mark.4, 4] / meta.fit[mark.1 :
mark.4, 5]
		meta.fit[mark.1 : mark.4, 7] <- 2 * (1 - pnorm(abs(meta.fit[mark.1 : mark.4, 6])))
		meta.fit[mark.1 : mark.4, 8] <- meta.fit[1 : 4, 4] + qnorm(0 + (1 - level) / 2) *
meta.fit[mark.1 : mark.4, 5]
		meta.fit[mark.1 : mark.4, 9] <- meta.fit[1 : 4, 4] + qnorm(1 - (1 - level) / 2) *
meta.fit[mark.1 : mark.4, 5]

		meta.fit[mark.1 : mark.2, 10 : 11] <- beta.cov.1
		meta.fit[mark.3 : mark.4, 10 : 11] <- beta.cov.2

		meta.fit[mark.5, 4] <- tau.sq.hat
		meta.fit[mark.5, 6] <- q.hat
		meta.fit[mark.5, 7] <- 1 - pchisq(q.hat, df = d.f)

		meta.fit[mark.5 + 1, 3] <- paste(k.estimator, “hat”, sep = “-“)
		meta.fit[mark.5 + 1, 4] <- n.miss.hat

		assign(“meta.fit”, meta.fit, env = .GlobalEnv)
	}
}
}