# Peer Reviewers

Dr. Michael Borenstein

Biostat, Inc.

Englewood, NJ

Professor Larry V. Hedges

Northwestern University

Evanston, IL

Dr. Alex J. Sutton

Department of Health Sciences

University of Leicester

Leicester, UK

Norma Terrin, Ph.D.

Tufts University

Boston, MA