# Appendixes

Appendix A Peer Reviewers

Appendix B Software Program Code

Appendix C Program Documentation

Appendix D Output From Example

Appendix E Tables