# Acronyms/Abbreviations

CI: Confidence interval
FE: Fixed effect
ICC: Intraclass coefficient
RE: Random effects