# Results

A total of 468 articles were identified through the literature search. After dual review of abstracts, 116 articles were pulled for full-text review. Additional articles from workgroup members and Key Informants (KIs) were also pulled for full-text review. After full-text review, a total of 53 articles were included and were categorized as: background (n=8), review of rapid review types (n=12), rapid review/product methods (n=30), and empiric studies evaluating rapid review/product methods (n=2). Of the 30 articles initially classified as rapid review/product methods, only those that described methods for a specific program or product (n=10) were included in the final analysis. A flow diagram of the search process is shown in Appendix C. The background articles and reviews of rapid review types were used to provide context for the introduction and background sections of this white paper. The other sets of papers are described in the sections below, including:

1. Characterization of Rapid Products and Their Methods (based on the literature review and KI interviews)
2. Comparing Systematic Review and Rapid Review Approaches (based on KI interviews and the literature review)
3. Empiric Evidence Comparing Rapid Products With Systematic Reviews (based on the literature review)

## Characterization of Rapid Products and Their Methods

In this section we integrate information extracted from studies that describe rapid response programs or products with information gathered from the KI interviews and, where possible, by examining actual examples of the products in question. Based on these two methods of data gathering, we identified 36 examples of rapid products produced by 20 organizations. The organizations represented were both public and for-profit and had a range of experience with rapid products, from several months to 25 years. Most organizations also had well-established programs and extensive experience producing standard systematic reviews or HTAs (e.g., 25 years). Only one organization did not conduct standard systematic reviews or HTAs. The volume of reports produced varied by organization and type of product, ranging from 3 to 5 per year to 300 to 400 per year.

Most organizations had a multidisciplinary staff that was involved in producing the rapid products (e.g., librarian or information scientist, statistician, economist, project coordinator, researcher); often these staff also produced the standard systematic reviews or HTAs, or had experience with these more comprehensive products. Moreover, most often staff had extensive experience with reviews and graduate-level or medical training. The number of personnel assigned to a given product varied from zero (a computer algorithm where the user enters query) to nine; however, most common was one to three staff for shorter timeframes and two to four staff for longer timeframes.

The target audience varied and included: hospitals, hospital management, health systems, health systems administrators, ministries of health, health plans, special interest organizations, societies, guideline development organizations, universities, medical manufacturers, industry, public health consultants, patients, clinicians, policy makers, and payers. However, health systems tended to dominate and few programs responded to requests from individuals not associated with a larger organization.

All organizations described a structured topic nomination process that took different forms (e.g., dedicated phone line, email or electronic submission). Most organizations engaged directly with the nominator to refine the topic, adjust the scope as needed, and establish user needs and timelines. In fact, very few did not mention involvement with the nominator to refine the topic and develop the review.

We analyzed this information in two different but complementary ways guided by the two aspects of the term “rapid review.” First, we summarize information on the rapid products according to their production time (i.e., how rapidly they are produced). Second, we divide rapid products into four categories based on the extent of synthesis—Evidence Inventories, Rapid Responses, Rapid Reviews, and Automated Approaches—and describe the methods used for each type of product. Appendix D provides four tables describing these products according to: (1) product scope and purpose, (2) comprehensiveness, (3) rigor and quality control, and (4) approach to analysis and conclusions.

### Description of Rapid Products by Production Time

Table 2 summarizes the scope, end-users, and purpose of rapid products by production time (more detailed information available in Table E-1). The sections that follow provide a narrative summary of timeframe and methods (detailed information available in Tables E2-4).

Table 2 Scope, end-user and purpose of rapid review products by timeframe

Timeframe (number of products) | Scope | End-Users | Purpose
Within 1 week (5 products) | - All products limited to single comparison; - 3 limited to emerging technology; - 4 limited number of questions; - 2 limited other aspects of scope; (comparisons, questions, outcomes) | Hospital administrators, payers, clinicians, policy makers | Give user a picture of available evidence and regulatory issues; coverage decisions; clinical decisions
< 4 weeks (6 products) | - All products limited to emerging technology; - 2 limited to single comparison; - 4 limited number of questions; - None limited the number of studies | Health system and hospital administrators, clinicians, payers, policy makers | Allow user to do own research; coverage decisions, purchasing decisions; assess the need for future research
4-8 weeks (11 products) | - 4 products limited to single comparison; - 4 limited to emerging technology; - 5 limited number of questions; - 2 limited the number of studies; - 4 limited other aspects of scope; (comparisons, questions, outcomes) | Policy makers, service providers, clinicians, hospital administrators, payers | Purchasing decisions; designing care delivery; clinical decisions; coverage decisions; policy; allow user to do own research
2-3 months (7 products) | - 5 products limited to single comparison; - 2 limited to emerging technology; - 4 limited number of questions; - 2 limited number of studies; - 1 limited other aspects of scope; (comparisons, questions, outcomes) | Hospital administrators, policy makers, research institutions, government, manufacturers, clinicians, payers | Research prioritization; background; purchasing decisions; practice decisions; coverage decisions
Minimum of 3 months (7 products) | - 3 products limited to single comparison; - 1 limited to emerging technology; - 5 limited number of questions; - 6 limited other aspects of scope; (comparisons, questions, outcomes) | Hospital and health system administrators, research institutions, government, industries, policy makers, payers | Policy; coverage decisions; purchasing decisions

#### Production Time: Within 1 Week

Timeframe. Five products from five organizations were completed within 1 week (up to 5 days). These products were referred to as: ultra-rapid review, scoping review, search and summary, mini-review, and “answers.” Time to completion ranged from 5 minutes (computer algorithm in which user enters query) to “less than 1 week.”

Methods. Typically, these products involved searching a limited number of electronic databases (1 to 3). The use of grey literature was generally limited; only two reported sources in addition to electronic databases. Most restricted the type of studies included; for example, one used existing reviews if possible, and another limited to controlled trials. Only one program reported that they reviewed the full text of articles. None of these products involved dual study selection or dual data extraction. Most focused on a limited number of extraction elements; two of them focused on only one outcome. Only one of the five products involved quality assessment and grading the quality of evidence. Most products involved some form of internal review (e.g., by director of the program), but none had external review (e.g., peer review). Most products provided a narrative review with minimal synthesis (i.e., integration of findings across studies). Two provided conclusions and/or recommendations; others allowed end-users to formulate conclusions.

#### Production Time: Less Than 4 Weeks

Timeframe. Six products from five organizations were completed in less than 4 weeks. Time to completion ranged from 5 to 10 business days to “less than 4 weeks.” These products were referred to variably, e.g., rapid response, brief, summary of abstracts, evidence inventory.

Methods. Most indicated that the literature search, in terms of electronic databases, was limited; however, most listed at least four databases that were routinely searched. Most reported use of grey literature; only two reported that no grey literature searching was done. Five products reported on language restrictions and all of these focused on English only. Four products described limiting the search dates to the most recent 5 years, one indicated that date restrictions were sometimes considered, and one indicated no date restrictions. The use of primary vs. secondary sources varied: three products reported including systematic reviews and HTAs and one product did not include other designs if a systematic review or HTA was available. In four products, there was no full text review; in addition, one product only performed full text review if the abstract was not sufficiently detailed, and one product performed full text review but for limited information. All products limited the number of extraction elements and two products did no data extraction. None of these products involved dual study selection or dual data extraction. None of the six products involved quality assessment or grading the quality of evidence. Most products involved some form of internal review (e.g., by director of the program), but none had external review (e.g., peer review). Five of the products involved no synthesis, while one product included a qualitative synthesis. One product included key messages and another included opinions of the review authors with caveats.

#### Production Time: 4 to 8 Weeks

Timeframe. Eleven products from eight organizations were completed in 4 to 8 weeks. These products were referred to variably, e.g., technology brief, evidence brief, evidence summary, evidence advisory, summary with critical appraisal, rapid response, rapid review, and HTA.

Methods. The extent of searching electronic databases varied considerably from 2 databases to “any and all” depending on the topic; the majority listed 4 to 5 databases. All conducted some searching of the grey literature. Five products described limiting to English language studies; only one product mentioned no language restrictions. Six mentioned possible limits to the search dates depending on the topic. Four products relied on existing systematic reviews or HTAs if available. Most indicated that they conducted full text review; in one case no data extraction was done. Five specifically mentioned that the number of extraction elements was limited. Only two reported dual study selection. One reported dual data extraction while two others reported extraction with verification by a second reviewer. Quality assessment was conducted in the majority of cases, with two specifically indicating no quality assessment. Five reported grading the quality of evidence, one reported that it had been done on occasion, and one reported that it was under consideration. Only two products described external peer review and in one case peer review was not always done. Where data were synthesized, a qualitative approach was used in all cases. None reported conducting a quantitative analysis. Five indicated that they provide conclusions and/or recommendations, two provide key messages, and four provide no conclusions or recommendations.

#### Production Time: 2 to 3 Months

Timeframe. Seven products from six organizations fell into this category where product completion averaged approximately 2 months, but ranged from 1-3 months to 2-4 months (i.e., all had an upper limit of more than 2 months as distinct from the previous category). These products were referred to variably, e.g., literature summary, emerging technology report, “rapid and responsive HTA,” HTA, evidence review, and “snapshot” review.

Methods. The extent of searching electronic databases was variable: two described searches as comprehensive, one limited searches to 3 electronic databases, and the other products listed examples of databases but did not provide detail on any limits. All but one product reported searching for grey literature. Of the four products that reported on language, all restricted to English only. Two indicated that searches were limited to the most recent 5 years, while two indicated that searches were sometimes limited by date. Only two products indicated that they rely on or preferentially use existing systematic reviews or HTAs. In five cases, reviewers conducted full text review, one did not, and one did not extract data. Additionally, three products reported that the number of extraction elements was limited. Only one product reported dual study selection, and no products reported dual data extraction. Three products did not do quality assessment, while two products did so in a limited fashion. Only two products reported grading the quality of evidence. Peer review was mentioned for only one product; however, three products mentioned external review by experts or manufacturers. Two products reported doing no synthesis, three reported a qualitative synthesis, and two reported conducting quantitative analyses when possible. Four products did not provide conclusions or recommendations, while three report conclusions but not recommendations.

#### Production Time: Minimum of 3 Months

Timeframe. Seven products from six organizations required a minimum of 3 months with maximum time to completion ranging from 4 to 8 months. These products were referred to variably, e.g., rapid review (in three cases), evidence check, streamlined review, and summary review.

Methods. The extent of searching electronic databases varied considerably: limits were described in three cases, while in another three cases the searches were described as not limited or “comprehensive.” Most reported use of grey literature; only one reported that no grey literature searching was done and the other indicated that grey literature searching was decided upon with the nominator. Six products reported on language restrictions and all of these focused on English only. Four products indicated restricting the search dates, either to the most recent 5 years or restrictions based on topic area and in discussion with nominator. In four cases, the product would rely on existing systematic reviews or HTAs if available; one of these was described as a review of reviews and would not include primary studies. In the majority of cases, reviewers conducted full text review. Four products limited the number of extraction elements; extent of data extraction was unclear for the remaining products. One product involved dual study selection, while methods for the remaining products were variable, e.g., sometimes a second person would check, or only check excluded studies. No products involved dual data extraction; four products reported single extraction with verification by another reviewer. Five products involved quality assessment, one indicated that quality assessment varies, and only one reported that no quality assessment was done. Four products indicated that grading of the quality of evidence was done, and one product indicated that this is at the discretion of the nominator. For four products, it was reported that external peer review was done. All products involved a qualitative synthesis; two specified that a quantitative synthesis is done if the data allow and one indicated that quantitative analysis is done at the discretion of the nominator. All products indicated that they provide conclusions and/or recommendations.

### A Typology of Rapid Review Products

Once the data on different dimensions of the review process had been extracted, it became clear that while the methods that rapid review products use are very heterogeneous, they can also be fairly readily grouped into four categories according to the level of synthesis: evidence inventories, rapid responses, what we chose to call true rapid reviews, and automated approaches.

- Evidence inventories list what evidence is available, and often other contextual information needed for making decisions, but do no synthesis and do not attempt to present summaries or conclusions.
- Rapid responses organize and evaluate the literature to present the end-user with an [underlined: answer] based on the best available evidence but do not attempt to formally synthesize the evidence into a new conclusion. Usually this means reporting the conclusions of guidelines or systematic reviews, but some rapid response products apply a best evidence approach and report the results of primary studies if no secondary sources are available.
- “True” rapid reviews perform a synthesis (qualitative, quantitative, or both) to provide the end-user with an answer about the direction of evidence and possibly the strength of the evidence.
- Automated approaches are databases of extracted study elements that use computer algorithms to generate meta-analyses in response to questions. These are very different than other rapid products or systematic reviews, in that the search, extraction and grading are dissociated from the analysis, which is performed according to preset computer programs. However, they do produce a synthesized conclusion in less than 6 months and therefore will be briefly described.

Ten organizations produced only one type of product, six organizations produced two types of products, and three produced three types of products. Four produced more than one version of the same category of products, either to maximize what could be produced in the time allowed, or because they had more than one end-user with distinct needs. It should be noted that these categories are somewhat subjective, and that numbers do not always add up because it was not possible to get information on all dimensions for all products. Therefore, the numbers reported below give a sense of frequencies but may not be representative or reproducible. We have linked to examples primarily from the Canadian Agency for Drugs and Technologies in Health (CADTH) because CADTH produces three of the four types and all the reports are publically available; we also included one report from the Center for Evidence Based Practice to illustrate variation.

#### Inventories

##### General Description

An example of an evidence inventory is the CADTH Literature Summary “Mobile Apps for Improving Health: Clinical Evidence.”19 This product presents a list of the publications available, organized by secondary sources, randomized controlled trials, and non-randomized controlled trials. The key message was “two systematic reviews, seven randomized controlled trials, and three non-randomized studies were identified regarding the use of nutritional and physical activity applications (apps) for promoting healthy lifestyles. No literature was identified regarding the use of nutritional and physical activity apps for preventing chronic disease.”19 This allows the reader to judge the extent of evidence and find it for themselves, but does not offer any answers about the direction of evidence. These products may be considered consultations and may assist decision makers in specifying the scope of their question(s).

We identified six examples of inventories produced by six organizations, four based in the United States and two in Canada. Terms used included Search and Summary, Literature Summary, Evidence Inventory, Rapid Review, Hotline Response, Product Brief, Reference list, and QwikNote. The length of time needed to produce them ranged from 3 days to 6 weeks, with most taking around 15 working days. The most commonly cited report length was 10 pages. They were generally described as a list of available studies (with either abstracts or links to full studies) that addressed the questions, generally organized in some kind of best evidence approach. One also included summaries of guidelines or systematic reviews if available. A couple included contextual information relevant to implementation, such as regulatory approval. Six appear to be aimed at system-level decision makers (health system, payer, policy maker). One producer also specified clinicians as end-users, but in the context of providing library services to practicing clinicians who did not have access to a librarian in their practice setting. When a statement of purpose was available, it generally described providing a picture of the available evidence, and/ or providing the information to make an initial decision about coverage, purchase, or implementation, often to determine whether further research was needed.

##### Methods for Time Reduction

Three products explicitly limited the scope of the report, either by limiting the number of comparisons and/or number of questions, or by limiting the product to emerging technologies with a small evidence base, but three did not mention limiting scope and none mentioned either explicit or implicit limits on the number of studies that could be included. Comprehensiveness was also generally not limited: three mentioned limiting the search to 1 to 2 databases, only one completely excluded grey literature while two put some limits. However, three inventories always set time limits on the literature search and one sometimes did. Three preferentially looked for existing systematic reviews or HTAs, one never included secondary studies, while all included primary studies. Only one undertook full text review and only three carried out even limited extraction. Rigor and quality control was tightly curtailed, however, with none carrying out dual selection or extraction, and only three undergoing internal review by a supervisor or internal expert. None underwent any external review. None synthesized the findings into a conclusion, beyond possibly whether there was enough evidence for a systematic review.

In summary, evidence inventories appear to be a rapid product that is targeted at hospital administrators and payers and is designed to demonstrate what evidence is available to make decisions, including whether investing in further review is worthwhile. They are not necessarily limited by scope or comprehensiveness, but because they do not attempt any evaluation (beyond organizing studies by study type) or synthesis, they are on average the fastest type of product to produce.

#### Rapid Responses

##### General Description

Two examples of rapid responses are the Center for Evidence Based Practice's (CEP) Evidence Advisories and CADTH's Summary of Abstracts. A CEP Evidence Advisory on administration of intravenous insulin reviewed and evaluated the available guidelines and concluded: “The guidelines suggest performing double-checks of insulin doses and insulin administration, but lack detailed information on personnel and practice. Neither of the guidelines provides references to specific studies supporting recommendations. [low-quality evidence].”20 A CADTH Summary of Abstracts on Short-Acting Intramuscular Olanzapine for Acute Agitation concluded: “Three non-randomized studies were identified regarding the clinical effectiveness of short-acting intramuscular (SAIM) olanzapine for the treatment of acute agitation associated with bipolar disorder or schizophrenia. One study comprised only patients with schizophrenia or schizoaffective disorder. Compared with ziprasidone, patients taking olanzapine had a greater length of hospital stay. The authors reported that second generation SAIM antipsychotics were not associated with a shorter length of stay than treatment with haloperidol, required more injections than haloperidol, and were more costly.”20 The report then goes on to describe two other studies. Both of these reports provide the reader with what the best available evidence suggests the direction of evidence is, but do not synthesize the body of evidence into an independent conclusion.

We identified 10 examples of rapid responses produced by 9 organizations, 3 based in the United States, 2 in the UK, 3 in Canada, and 1 in Australia. Terms used included answers, evidence advisory, rapid response, tech note, and Responsive Innovation Evidence Review. The time taken to complete them ranged from 5 days to 3 months, with most time estimates falling around 1 to 2 months. Report length (where information was provided) ranged from 1 to 15 pages, with under 10 pages being the most common. Of the products that targeted particular end-users, four were intended to be used by policy makers or health system administrators and one by payers for purchase or coverage decisions. Three were intended to be used by clinicians and one by service providers to support clinical care or design care delivery. (Note: some products had more than one targeted end-user).

##### Methods for Time Reduction

Scope was not necessarily a limiting factor—three specifically limited the scope, four did not, and three sometimes did. Some specifically mentioned that they were willing to consider broad and complicated questions. Only one was limited to new or emerging technologies. However seven limited the number of questions that could be asked and three either explicitly limited the number of studies that could be considered or else adjusted other parameters to ensure that the number of studies was not overwhelming. Of note, the rapid response that was produced in under 5 days was the most tightly constrained—limiting scope, number of questions, number of studies, and focusing on new technologies.

The number of databases searched ranged from two to four and several reported a recursive approach, stopping the search as soon as enough data was acquired. Only two excluded grey literature, although two set limits. Five of the 10 rapid response products limited search dates, usually to the past 5 years, and a couple sometimes restricted inclusion to applicable settings. For the nine products for which this information was available, all preferentially used systematic reviews or guidelines; primary studies were only used if there were no reliable and recent systematic reviews. One product was only created if systematic reviews were available. For those for which data were available, about five did full text review, while three did not, but only limited extraction was done. There was no dual review or extraction (although there was oversight in one case). Four underwent internal review, one occasionally underwent internal review, and only one occasionally might go for external peer review—although some producers viewed public posting as a kind of peer review.

Although most did not assess quality or risk of bias, two did and one sometimes evaluated the strength of the evidence. Three reported some level of qualitative synthesis (although without doing a quality assessment), and none attempted quantitative synthesis. The level of conclusion was generally presented as a summary of the best evidence, or a narrative discussion of the best evidence, with perhaps key messages or points to consider.

In summary, as their name implies, rapid responses attempt to give a quick answer based on the best available evidence to support a purchase or clinical decision, and less often a coverage decision. There is more limitation of scope and comprehensiveness than with inventories. However, the key time saving is achieved by skipping synthesis and instead relying on existing systematic reviews or guidelines to provide a reasonably reliable answer.

#### Rapid Reviews

##### General Description

An example of a rapid review is CADTH's summary with critical appraisal “Bariatric Surgical Procedures for Obese and Morbidly Obese Patients.”21 This report described and critiqued the available studies, and qualitatively synthesized the results to produce a conclusion that encompassed the totality of the evidence:

Results consistently demonstrated that Roux-en-Y gastric bypass (RYGB) was associated with a greater weight reduction relative to laparoscopic adjustable gastric banding (LAGB), but was also associated with a higher risk for procedural adverse events and a longer duration of hospitalization after the procedure. The evidence of effectiveness and safety for sleeve gastrectomy suggested that it is less effective than RYGB for weight loss but associated with a reduced risk for complications, and more effective for weight loss compared with LAGB, but also more likely to result in complications, but evidence was conflicting.21

This approach gives the reader an answer based on a new synthesis of the evidence and is most similar to a standard systematic review.

We identified 18 examples of rapid reviews produced by 15 organizations, 6 based in the United States, 2 in the UK, 3 in Canada, 3 in Australia, and1 in Italy. Terms used included rapid reviews, evidence reviews, emerging technology report, streamlined review, summary review, evidence check, evidence summary, CompNote, Summary with critical appraisal, and Tech Brief. The time taken to complete them ranged from 3 days to 6 months, with most time estimates falling around 2 to 4 months. Report length (where information was provided) ranged from 1 to 150 pages, with 20 pages being the most common. Of those that defined an audience, seventeen were intended to be used by payers, policy makers, or health system administrators for coverage or purchase decisions, and only one was intended to be used by clinicians.

##### Methods for Time Reduction

Careful scoping appears to be the primary way most rapid reviews achieved their deadlines. Twelve limited the scope to a single comparison (another did sometimes), 8 limited questions to emerging technologies where it was known the evidence base would be sparse, 11 limited the number of questions that could be considered (1 did sometimes), and 15 limited the number of studies that could be included in the final report, either explicitly or through adjusting the scope. In some cases, a maximum number of studies were set and if the initial search went past the limit, the scope would have to be further reduced or the topic would have to be promoted to a standard systematic review. A few limited the number of database searches, but more said they used the same search pattern as for standard systematic reviews. Grey literature was excluded for only one, although four reported limited or variable use of grey literature. Nine always or sometimes set date limits on searches and a few used study size to limit inclusion. Ten used existing systematic reviews preferentially, but often mentioned updating them and only one never used primary studies. However five preferentially used primary trials, with existing systematic reviews used as reference sources or background if at all. Only one did not always do a full-text review, but almost all significantly restricted the number of items that were extracted. About a third had some kind of check on screening and extraction (although only one did full dual screening). Eleven had internal review, while 10 had some form of external review, either external experts or peer review. Sixteen did quality rating of the included studies, while 10 formally rated the strength of evidence and 2 did sometimes or were considering doing so. All performed qualitative synthesis while seven also performed quantitative synthesis and some did both (six). All provided conclusions, although some added a number of caveats.

In summary, this type of report appears to be the most comparable to a standard systematic review, albeit one with a tightly constrained scope and that often sacrifices quality control measures in order to provide a timely response.

##### Automated Approaches

Two of the products that were identified in our search for rapid reviews did not fit neatly into the three categories described above. However, because they involved a systematic search and synthesis of the evidence to produce an answer about the direction and strength of evidence, we felt they met our broad inclusion criteria. Both products were essentially algorithms attached to search engines and databases of extracted studies that can be used to produce meta-analyses on command. Because we only had two examples, we were not comfortable making general observations about this type of rapid product. However, it is important to note that they do exist and represent a potentially attractive strategy to provide timely evidence for decision making and to support clinical care, given the labor intensive nature of most evidence reviews. Empiric research regarding the accuracy and reliability of these approaches is needed.

## Comparing Systematic Review and Rapid Review Approaches

### Philosophical Differences Distinguishing a Systematic Review and a Rapid Review

Through our interviews with a large number of organizations who develop rapid products, it became clear that the development of a rapid product in most cases is not simply a “mini-systematic review with corners cut” but that the very essence of developing rapid products differs from that of systematic reviews. Table 3 describes thematic differences that arose from interviews. These core differences in large part explain the observed differences in products.

Table 3 Philosophical approaches to rapid and systematic reviews (based on Key Informant interviews)

Product Features | Rapid Review | Systematic Review
Emphasis/Priority | End-user: Provide information to help a specific decision maker make a decision | Product: Conduct a comprehensive, unbiased and rigorous systematic review (often with multiple stakeholders in mind)
Relationship With End-User | Continuous intimate relationship with a specific end-user in iterative fashion throughout work to ensure product will meet end-user's need | Arms-length relationship with end-users engaged at specific time points, and review group separated from end-users during certain phases to reduce bias
Role of Other Reviews | Often high reliance on systematic reviews for information | Often limited use of reviews. Systematic reviews one among many sources. The primary role of systematic reviews may be to identify primary studies
Organizational Features/Staffing | High reliance on maintaining highly trained staff to conduct reviews | Useful to have experienced staff but not essential (e.g., more time/possibility to train staff during conduct of the review)
Spectrum of Products | Broad range – feature determining type of product is time allowed and needs of decision maker | Consistent comprehensive product
Scope | More routinely focused question | Range from focused to broad questions

One of the biggest differences between rapid products and standard systematic reviews is the relationship with the stakeholder. In many ways, this feature drives other differences. Rapid products are often conducted to help a specific end-user make a specific decision in an identified timeframe. Because of this, the question for the reviewer is often what can be provided in the time allowed. This in large part explains the broad portfolio of products often produced by rapid response groups (ranging from lists of relevant studies and guidelines to reports that include synthesis and evidence grading) and differences in formats compared with systematic reviews. The often compressed timeframe also explains the choice of some groups to rely heavily on prior systematic reviews and different presentation formats. Finally, maintaining a highly skilled staff is especially critical to rapid response groups who need to produce reports in a short timeframe and understand the type of products that might meet the needs of the decision maker.

### Differences Between a Systematic Review and a Rapid Product

Few rapid products encompass all the characteristics of a comprehensive systematic review. The following list highlights some key differences identified by the Key Informants (KIs) at the various stages of a systematic review. We compare these strategies to systematic reviews produced through the EPC Program.

- Research question: The research question for a rapid product is generally narrower than a systematic review. Systematic reviews produced through the EPC Program often answer several broad overarching questions whereas rapid products commonly limit the number and scope of questions that they answer. KIs commonly mentioned focusing on new or emerging technologies (which have limited evidence) or single interventions or therapies within a narrow population.
- Topic refinement: Rapid response groups generally work closely with the nominator (or end-user) to refine the topic. The topic refinement process for a rapid product often involves a single reviewer meeting with an individual requestor, either via email or telephone. The scope and research question is often determined in a matter of days or weeks. Within the EPC Program, the topic refinement process for standard systematic reviews involves a team of reviewers working with a group of technical experts over an extended period of time, often up to several months.
- Literature search: The literature search for a systematic review is extensive, including multiple databases as well as grey literature searching, with a goal of capturing all available evidence on a given topic. Rapid responses often limit the search with very few organizations interviewed regularly searching more than five databases. Most organizations relied on Cochrane, PubMed and Medline and less than half of the rapid products included a search for grey literature. Some organizations described stopping a search when “enough” evidence was found and using only existing systematic reviews
- Literature Screening/Extraction: Systematic reviews often use a dual review process for full text article review and data extraction whereas most rapid response groups utilized a single reviewer and some did not include full text review. Most rapid products include data extraction performed by one person and some rapid products do not include any data extraction or severely restrict the number of data items extracted.
- Synthesis: While it is common to perform quantitative analyses in systematic reviews, very few rapid products involved quantitative synthesis. Some rapid products included a qualitative analysis while some did not include any synthesis.
- Review: Systematic reviews produced through the EPC Program often involve extensive internal and external review. Internal review follows a structured process with input from the Program and an arms-length editor from another EPC. External review involves public posting and traditional peer review. Some rapid products included an internal review and few included external review.
- Overall process: Overall systematic reviews are more comprehensive in their approach; those conducted through the EPC Program follow established methods and procedures. Rapid products have greater variation in methodological practices in order to achieve a product in a shortened time span.

### Potential Concerns in Conducting Rapid Reviews

Several of the interviewed organizations expressed concerns in developing rapid products. Due to the shortened timeline of the products, the process often involves a narrow and/or a limited selection and review of the literature. This process increases the risk of missing evidence. Additionally, the shortened timeline under which to review and consider the available evidence limits the thought process. This can trigger inherent uncertainty in the findings of a rapid product. Another concern expressed by rapid product producers is that the final products may be mistaken as full systematic reviews by certain requestors (i.e., reviews that have followed accepted standards for systematic reviews). This may especially be a concern for organizations that produce both full systematic reviews and rapid products. Explicitly outlining the trade-offs and limitations of a rapid product as compared with a systematic review at the beginning of the process can help to eliminate the chances of the rapid product being interpreted as a comprehensive review. Further, some organizations place disclaimers on the report in an effort to avoid any misinterpretation of what the product offers.

### Empiric Evidence Comparing Results of Rapid Products With Systematic Reviews

Electronic and hand searches identified 12 studies that appeared to represent empiric evidence comparing results of rapid products with systematic reviews but only two studies presented empiric evidence related to this current project.14,22,23 Both studies were conducted in the context of HTAs.

Van de Velde et al.23 presented a case study comparing results of a rapid review on potato peels for burns with those of a systematic review. The authors reported that the rapid review identified three RCTs, which was two more than were included in the systematic review. The results and conclusions of the two reports were different. However, the limited detail on the methods used to conduct the systematic review makes this case study of little value for our purposes.

In 2007, the Australian Safety and Efficacy Register of New Interventional Procedures – Surgical (ASERNIP-S)14 examined the use of rapid reviews in HTA. As part of the report, the authors compared the results and conclusions of rapid reviews with those of full systematic reviews or HTA reports. They searched websites of HTA agencies to identify rapid reviews on surgical interventions published between 2001 and 2004. Rapid reviews were defined as “any HTA report or systematic review that took between 1 and 6 months to produce and included a comprehensive or systematic literature search.” The rapid reviews were then matched with a full systematic review (i.e., production was not limited by time), written on the same topic, and produced within 1 year of the matching rapid review.

Seven rapid reviews with matching full reviews were identified. The reviews addressed four topics: drug eluting stents, lung volume reduction surgery, living donor liver transplantation, and hip resurfacing. For living donor liver transplantation, there was one rapid review; for the remaining topics there were two rapid reviews each. The authors presented the clinical outcomes (safety and efficacy) discussed by each review, as well as the overall conclusions, the scope of the report, and the methods used.

Differences in methods were identified between rapid and full reviews. The methods and results of full reviews were reported in more detail than the rapid reviews. Some rapid reviews included only systematic reviews or HTAs, while others conducted searches for and included primary studies. Most rapid reviews were written by single authors or authorship was not reported. Most rapid and full reviews underwent an external review. Searching was not consistently more extensive in full reviews (based on number of databases searched). Full reviews tended to assess the quality of primary studies, while rapid reviews either did not or did not report. Despite these differences, there were no instances in which the essential conclusions of the rapid and the full reviews were opposed. The full reviews consistently provided greater depth of information and more detailed recommendations pertaining to the implementation of each surgical intervention. The authors commented that full reviews may be more appropriate to identify safety outcomes and risk factors associated with an intervention.

The comparisons between rapid and full reviews are limited to the context of HTAs, which are often driven by need for more rapid advice on explicit decisions about use of new health technologies, many with very limited published evidence. Due to the context and the relatively small volume of research, the HTA-based assessments may be only modestly applicable to broader topical systematic reviews with much larger bodies of evidence.