# References

1 Higgins JP, Green S. Cochrane handbook for systematic reviews of interventions Version 5.1.0. [updated March 2011]. Cochrane Collaboration. Cochrane Collaboration. 2012.
2 Morton S, Levit L, Berg A, et al. Finding What Works in Health Care: Standards for Systematic Reviews. National Academies Press. 2011.
3 Umscheid CA, Williams K, Brennan PJ. Hospital-based comparative effectiveness centers: translating research into practice to improve the quality, safety and value of patient care. J Gen Intern Med. 2010;25(12):1352-5. [pmid: 20697961].
4 Khangura S, Polisena J, Clifford TJ, et al. Rapid Review: An emerging approach to evidence synthesis in health technology assessment. Int J Technol Assess Health Care. 2014:1-8.
5 Eden J, Levit L, Berg A, et al. Finding what works in health care: standards for systematic reviews. Washington, DC. National Academies Press. 2011.
6 Latham J, Murajda L, Forland F, et al. Capacities, practices and perceptions of evidence-based public health in Europe. Euro Surveillance. 2013;18(10):13.
7 Lehoux P, Tailliez S, Denis J, et al. Redefining health technology assessment in Canada: diversification of products and contextualization of findings. Int J Technol Assess Health Care. 2004;20(3):325-36. [pmid: 15446762].
8 Brassey J. Liberating the literature: Rapid versus systematic reviews. 2012. http://blog.tripdatabase.com/2012/04/search-was-undertaken-to-identify.html. November 2013.
9 Watt A, Cameron A, Sturm L, et al. Rapid versus full systematic reviews: validity in clinical practice. ANZ Journal of Surgery. 2008;78(11):1037-40. [pmid: 18959712].
10 Harker J, Kleijnen J. What is a rapid review? A methodological exploration of rapid reviews in Health Technology Assessments. Int J Evid Based Healthc. 2012;10(4):397-410. [pmid: 23173665].
11 Ganann R, Ciliska D, Thomas H. Expediting systematic reviews: methods and implications of rapid reviews. Implement Sci. 2010;5(1):56. [pmid: 20642853].
12 Andradas E, Blasco J, Valentín B, et al. Defining products for a new health technology assessment agency in Madrid, Spain: a survey of decision makers. Int J Technol Assess Health Care. 2008;24(01):60-9. [pmid: 18218170].
13 Nielsen C, Funch T, Kristensen F. Health technology assessment: research trends and future priorities in Europe. J Health Serv Res Policy. 2011;16(suppl 2):6-15. [pmid: 21737525].
14 Cameron A. Rapid versus full systematic reviews: an inventory of current methods and practice in Health Technology Assessment. ASERNIP-S. 2007.
15 Dennett L, Chojecki D. Rapid searches for rapid reviews. HTAi Annual Meeting. 2013. Bilbao, Spain.
16 Thomas J, Newman M, Oliver S. Rapid evidence assessments of research to inform social policy: taking stock and moving forward. Evidence & Policy. 2013;9(1):5-27.
17 Scott A, Harstall C. Utilizing diverse HTA products in the Alberta health technologies decision process: work in progress. Institute of Health Economics. Edmonton AB. Institute of Health Economics. 2012.
18 Vestergaard M, Ehlers L, Kidholm K, et al. Introduction to mini-HTA–a management and decision support tool for the hospital service. Danish National Board of Health-Center for Evaluation and HTA. 2005.
19 Mobile Apps for Improving Health: Clinical Evidence. Canadian Agency for Drugs and Technologies in Health. CADTH. May. 1. 2014. www.cadth.ca/media/pdf/htis/may-2014/RA0679%20Mobile%20Apps%20for%20Health%20Final.pdf. July 1, 2014.
20 Short-Acting Intramuscular Olanzapine for Acute Agitation. Canadian Agency for Drugs and Technologies in Health. CADTH. April. 24. 2014. (http://www.cadth.ca/media/pdf/htis/may-2014/RB0671%20IM%20Olanzapine%20Final.pdf). July 1, 2014.
21 Bariatric Surgical Procedures for Obese and Morbidly Obese Patients: A Review of Comparative Clinical and Cost-Effectiveness, and Guidelines. Canadian Agency for Drugs and Technologies in Health. CADTH. April. 24. 2014. http://www.cadth.ca/media/pdf/htis/jun-2014/RC0544-000%20Bariatric%20Surgery%20Final.pdf. July 1, 2014.
22 Egger M, Juni P, Bartlett C, et al. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews?: Empirical study. National Coordinating Centre for Health Technology Assessment. 2003.
23 Van de Velde S, De Buck E, Dieltjens T, et al. Medicinal use of potato-derived products: conclusions of a rapid versus full systematic review. Phytotherapy Research. 2011;25(5):787-8. [pmid: 21110396].
24 Hailey D, Corabian P, Harstall C, et al. The use and impact of rapid health technology assessments. Int J Technol Assess Health Care. 2000;16(02):651-6. [pmid: 10932429].
25 Dobbins M, Jack S, Thomas H, et al. Public Health Decision-Makers' Informational Needs and Preferences for Receiving Research Evidence. Worldviews on Evidence-Based Nursing. 2007;4(3):156-63. [pmid: 17850496].
26 Dobrow M, Goel V, Lemieux-Charles L, et al. The impact of context on evidence utilization: a framework for expert groups developing health policy recommendations. Soc Sci Med. 2006;63(7):1811-24. [pmid: 16764980].
27 Thomson H. Improving Utility of Evidence Synthesis for Healthy Public Policy: the Three Rs (Relevance, Rigor, and Readability [and Resources]). Am J Public Health. 2013;(0):e1-e7.