# Methods

## General Approach

We took a two-pronged approach to meet our objectives, combining a review of the literature with Key Informant (KI) interviews of key producers of rapid products to develop a broad picture of what is considered a rapid review/product, the strategies used to make the products rapid, and the context in which such products are produced. A workgroup of members from EPCs, the Scientific Resource Center (SRC), and AHRQ participated in twice monthly workgroup teleconference calls over the course of 10 months to discuss project direction and scope, assign and coordinate tasks, collect and analyze data, and discuss and edit draft documents.

## Literature Search

In October and November 2013, we searched Ovid Medline, Ovid EBM Reviews, Cochrane Methodology Register, and SRC Methods Library, and performed a Scopus citation reference search and a grey literature search to identify papers about rapid reviews or similar products. High value keywords were identified by workgroup members. The final search strategy appears in Appendix A.

We sought to identify literature that: (1) discussed rapid review methods; (2) discussed initiatives or programs producing rapid reviews; or (3) provided empiric evidence on rapid review methodology. We also identified examples of published rapid reviews. We limited inclusion to articles describing rapid products within the health care field.

Early on we realized that the terminology used to describe rapid products is extremely varied. As we were interested in understanding broadly how these products are defined and conducted, we sought to be inclusive. During our screening we encountered the concept of mini-HTAs. Mini-HTAs are described as a “management and decision support tool”18 and typically consist of a form or checklist containing several questions corresponding to the domains of a standard HTA report which may be answered based on the literature, a survey, and expert opinion. We excluded mini-HTAs from this report because they are a checklist that serves to guide decision making and not a method to evaluate evidence.

Abstracts were dual reviewed by investigators using ABSTRACKR software (available at http://abstrackr.cebm.brown.edu). Discrepancies were resolved by a third investigator. Full-text articles were independently reviewed by two investigators for inclusion. Articles suggested by workgroup members or Key Informants were also reviewed for relevance using the same methods. Different groupings of articles emerged during full-text review including: (1) background papers on rapid product methods, programs, or contextual factors; (2) previous articles of rapid product types; (3) descriptions of rapid products, including the methods used to produce them; and (4) empiric data exploring differences resulting from rapid products and standard systematic review methods. Groupings are not mutually exclusive. Articles in groups 1 and 2 provided context and contributed to the introduction and discussion sections of this report. Data from articles in groups 3 and 4 were extracted, synthesized and informed the results.

We reviewed papers that gave an overview or theoretical description of rapid products and used these to develop items for a table of products. First, we developed a set of questions to describe the products and a framework of dimensions of the process that can be altered to make a review more rapid (Table 1). The purpose of this table was to identify which aspects of the standard systematic review process are most and least often altered to accelerate the review process, whether specific shortcuts are associated with specific features of a review, and what the implications are for the utility of the final product. We also identified a set of questions to allow us to describe the context in which the reviews are created, such as how long the producer has been preparing rapid products, the relationship with the nominator, and the number and knowledge-level of the staff.

Table 1 Dimensions of standard systematic reviews that may be altered in rapid products

Dimension | Possible Alterations
Scope | Limit the type of questions (e.g., efficacy only, new technology only, single technology only)
Scope | Limit number of questions
Scope | Limit number of studies that can be included
Comprehensiveness | Limit search strategy (e.g., number of databases, grey literature, date, setting, language)
Comprehensiveness | Limit study types included (e.g., existing systematic reviews only, RCTs only)
Comprehensiveness | Limit textual analysis (e.g., no full-text review, limit number of extraction items)
Rigor/Quality control | Eliminate dual study selection
Rigor/Quality control | Eliminate dual data extraction
Rigor/Quality control | Limit or eliminate internal or external review of final product (e.g., peer review)
Synthesis | Limit or eliminate risk of bias/quality assessment of individual studies
| Limit or eliminate either quantitative or qualitative analysis
| Limit or eliminate strength/quality of evidence assessments (e.g., using GRADE)
Conclusions | Simplify or eliminate any conclusive statements about the direction of the evidence

Details about reports and programs from articles that described actual rapid reports or programs were extracted into the table of examples, and samples of those rapid reports were used to crosscheck the information from the articles whenever possible. Studies that empirically compared the results of rapid products with standard systematic reviews were extracted and analyzed separately.

## Key Informant Interviews

In parallel with the literature search, we conducted interviews with producers of rapid products, in both the public and private sector. We invited 19 Key Informants (KIs) to participate in a 60-minute individual telephone interview between January and March of 2014. Seventeen interviews were conducted with 18 KIs. The KIs were selected from organizations known by members of the workgroup to produce rapid products or offer rapid response services. No restrictions were placed with respect to geographic location; however, we were only able to conduct interviews with KIs who could communicate in English. We sought KIs from organizations around the world that are recognized for work in this area. Based on a comparison of KI interviews with the literature review, we are confident that we spoke with most of the prominent producers of rapid products in the English language.

Each KI completed an “EPC Conflict of Interest Disclosure Form” prior to being interviewed and no disclosed conflicts precluded participation of any of the invited organizations. KIs were interviewed about their methods for and experiences in developing rapid products following an interview guide developed by the workgroup (Appendix B). All interviews were digitally recorded, transcribed, and reviewed to identify and code themes using NVivo software (QSR International). Relevant information on rapid products was compiled in an extraction table.

The details of specific rapid products described in the interviews were extracted by one researcher and reviewed by at least one other and combined with data extracted from the literature examples to create a combined table of examples of rapid products. Some of the examples are informed only from the literature, some only by the interview, and others by both. While this approach has some drawbacks―in general we have less detail about rapid products available only through the literature—it allowed us to create a larger and richer set of examples than would have been available though one approach alone. For the examples derived from the interviews, we sent the tabulated information back to the interviewees for review; we received responses from 10 of the organizations.