# Introduction

## Background

Systematic reviews provide comprehensive and rigorous syntheses of evidence to answer clinical and policy questions; however, they are complex undertakings requiring substantial time and resources to meet currently accepted standards.1,2 It is not uncommon for standard systematic reviews to take one or even two years to complete. Increasingly, clinicians, policy makers, and other decision makers are requesting evidence in shorter timeframes to support their needs;3 however they still expect transparent, unbiased, and reliable evidence products.4 In response, the concept of “rapid reviews” has emerged within the arena of evidence synthesis to describe a review type that can be completed more quickly than a standard systematic review.4

Given the considerable time and resource requirements to produce systematic reviews that comply with endorsed standards,5 it is not surprising that the intuitively appealing concept of rapid reviews has gained considerable attention recently within communities that produce or rely on systematic reviews. For example, sessions on rapid reviews have been offered at the most recent annual symposia of The Cochrane Collaboration and Guidelines International Network (G-I-N). Further, Cochrane Innovations, a trading company owned by The Cochrane Collaboration, has initiated a rapid response program, and a formal methods group is being proposed within the Collaboration with a focus on rapid reviews. A 2012 survey of European Health Technology Assessment (HTA) and public health organizations suggested that rapid reviews are offered by 70 percent of these agencies.6,7

This surge in interest poses two challenges to existing systematic review programs. First, should rapid reviews be offered, and what components are needed to build a successful program? Second, can some rapid review methods be adapted to make standard systematic reviews more timely? Answering these questions depends on understanding what methods rapid reviews use to achieve their more timely results, and to what extent those methods increase the risk of bias and error. Systematic reviews take time because they employ multiple methodologies to ensure that all relevant data have been identified and accurately analyzed. These time-consuming methodologies have been developed to minimize bias in the final conclusions, and therefore eliminating some or all of them may result in biased conclusions.

Answering these questions is more complicated than it appears. In order to consider offering rapid reviews, one first has to be able to define what they are. Previous reviews on the topic of rapid reviews describe them as “ill-defined,”8 “not well-defined,”9 lacking a single definition,10 or “varying widely in terms of the language used to describe them.”11 HTAs may also be rapid, and so HTA may be part of the title of such reviews. Given the wide range of terms used to capture these short, focused reviews (rapid review, evidence advisory, evidence inventory, hotline response, etc.), we use the term “rapid products” in this report to capture the range of types of rapid reports.

Not only the names, but also the timelines vary considerably. Andradas et al. described rapid reviews as brief, readable, and usable responses to guide decision making that are typically completed within 6 months, which we have also chosen to use as part of our working definition of a rapid product.12,13 Previous reviews have focused specifically on rapid HTAs and while multiple reviews describe these as taking between 1 and 6 months,9,10,14 others described products taking as little as 1 week.15 Automated approaches that generate meta-analyses in response to user-defined queries, sometimes called an “ultra-rapid review,” are an outlier product that takes mere minutes to complete.

Finally, rapid products employ a wide range of strategies to reduce the time required to produce the final report, and an even wider range of combinations of strategies. This includes different methods used to identify relevant literature,10,14,15 different approaches to assessing quality,10,14 and variation in the types of syntheses conducted.8,14,10,16 Authors of one review even argued that rapid products “defy definitive categorization because of their heterogeneous timelines, components, search strategies, and methodologies.”17 However, given the growing interest in these rapid products and the ever-present pressure to produce reliable evidence on more topics more quickly, it is imperative that a better understanding be developed.

## Purpose of This Report

Since 1997, the Agency for Healthcare Research and Quality's (AHRQ) Evidence-based Practice Centers (EPCs) have been recognized as leaders in conducting comprehensive systematic reviews that shape health policy, inform national scientific conferences, and assist stakeholders in health care decision making. Topics for EPC reviews may be nominated by individuals or specific organizations; however, the reports are prepared with the intent of being applicable to and usable by a broad audience. Currently, the typical process for the production of a systematic review within the EPC Program follows a number of steps including topic nomination, topic triage, topic refinement, and completion of the full review, and can take as long as 2 years. While these reviews are recognized for their breadth and methodological rigor, they cannot be commissioned by stakeholders to provide evidence to support decisions that need to be made urgently.

Given the critical importance of having valid evidence syntheses available in a timely manner for use by a myriad of health and health care decision makers, the AHRQ EPC Program commissioned a white paper on rapid reviews. The goal of this white paper is to understand the range of products that are considered rapid, their intended purposes and the contexts in which they are commissioned, and how methods and required resources differ (e.g., how they gain efficiency) between products and from standard systematic reviews. Ideally, this white paper will also identify available empiric data to judge the impact of specific methodological shortcuts on the reliability, validity, and usability of these rapid products. Further, the perceived value of these rapid products by end-users, particularly in light of different methodological trade-offs, needs to be understood.

We sought to build on previous work by not simply describing how methods vary between rapid products and standard systematic reviews, but by identifying which variations are important and how the context in which they are produced influences variations in methods used. We also sought to understand the approach to rapid products that different organizations have taken particularly in the context of the purpose of the reports, those requesting the reports, the types of decisions being informed, the setting and structure of the rapid product developer, and the relationship between the developers and users of the reports. The following probing questions guided this work: What are the characteristics of rapid products produced by key organizations and described in the literature (e.g., purpose, audience, timelines, and personnel)? What methodological guidance exists for the conduct of rapid products? What empiric evidence exists comparing the results of rapid products with systematic reviews?