# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Samantha Barker, B.S.
  Senior Project Manager, Evidence Synthesis and Research Funding Program
  Institute for Safety, Compensation and Recovery Research (ISCRR)
  Melbourne, Victoria, Australia
- Bob Battista, M.B.A.
  Chief Executive Officer
  Doctor Evidence
  Santa Monica, CA
- Suzanne Belinson, Ph.D., M.P.H.
  Executive Director, Technology Education Center
  Blue Cross Blue Shield Association
  Chicago, IL
- Jon Brassey, B.Sc.
  Director
  TRIP Database, Ltd.
  Bristol, UK
- Tammy Clifford, M.D., Ph.D.
  Vice President, Strategic Initiatives
  Chief Scientist, Canadian Agency for Drugs and Technologies in Health (CADTH)
  Ottawa, Ontario, Canada
- Nicole Floyd, M.P.H.
  Program Manager
  VA Evidence-based Synthesis Program (ESP) Coordinating Center
  VA Portland Health Care System
  Portland, OR
- Sarah Garner, Ph.D., BPharm
  Associate Director R&D
  National Institute for Health and Care Excellence (NICE)
  London, UK
- Chantelle Garrity, B.A., DCS, M.Sc.
  Senior Research Program Manager
  Ottawa Health Research Institute (OHRI)
  Knowledge Synthesis Group
  Ottawa, Ontario, Canada
- Marguerite Koster, M.A., M.F.T.
  Practice Leader, Technology Assessment & Guidelines Unit
  Kaiser Permanente
- Susan Levine, M.S., D.V.M., Ph.D.
  Chief Scientific Officer, Consulting Hayes, Inc.
  Lansdale, PA
- Guy Maddern, M.B.B.S., Ph.D., M.S., M.D., FRACS
  Surgical Director
  Australian Safety and Efficacy Register of New Interventional Procedures—Surgical
  Adelaide, South Australia, Australia
- Marco Marchetti, M.D.
  Director, Health Technology Assessment Unit
  Policlinico Universitario Agostino Gemelli
  Rome, Italy
- Marian McDonagh, Pharm.D.
  Associate Professor
  Oregon Health & Science University (OHSU)
  Portland, OR
- Kim Peterson, M.S.
  Research Associate
  VA Evidence-based Synthesis Program (ESP) Coordinating Center
  VA Portland Health Care System
  Pacific Northwest Evidence-based Practice Center (PacNW EPC), OHSU
  Portland, OR
- Sian Rudge, MIPH
  Director, Knowledge Exchange Division
  Sax Institute
  Haymarket, New South Wales, Australia
- Karen Schoelles, M.D., S.M., FACP
  Director
  ECRI Evidence-based Practice Center
  Plymouth Meeting, PA
- Lesley Stewart, Ph.D.
  Director
  University of York Centre for Reviews and Dissemination (CRD)
  York, UK
- Craig A. Umscheid, M.D., MSCE
  Director
  Penn Medicine Center for Evidence-based Practice
  Assistant Professor of Medicine and Epidemiology
  University of Pennsylvania
  Philadelphia, PA