# Discussion

Our review of the literature and interviews with prominent producers of rapid products confirms the findings of previous reviews that there is a range of products that are being used to support evidence based decisions that can be produced more quickly than standard systematic reviews. Further, the terms used to describe rapid products and the methods they employ vary widely.

Our analysis of these products by production time generally showed that increasing amounts of time allowed incorporation of more of the standard systematic review methods and quality control mechanisms. For example, the most rapid products (within 1 week) generally: searched a limited number of databases; limited use of grey literature; restricted the types of studies included; did not conduct full text review; did not perform dual study selection or data extraction; focused on a limited number of extraction elements (e.g., only one outcome); did not do quality assessment or grading; provided a narrative review at most with minimal synthesis; and provided minimal conclusions and/or recommendations. Further, none of the most rapid products underwent external peer review. As the timeframes increased many of these limitations were lifted, e.g., more databases searched, use of grey literature and full text review. However, even among the products that took longer to complete (minimum 3 months and up to 8 months), there were variable limitations on database searching, language (i.e., using English only), and search date (e.g., using the most recent 5 years). Further, some relied on existing systematic reviews or HTA reports if available. While there was an increase in full text review with increased production time, the number of extraction elements was still generally limited. In addition, use of dual study selection was variable; most did single data extraction, with data verification by another reviewer at most. Among the reviews with longer production timeframes, there was an increase in the frequency of quality assessment, evidence grading, and external peer review.

To gather a better understanding of the variation, we categorized products based on the extent of synthesis performed, and found that we could describe four distinct types of products, with slightly different approaches and audiences.

- Inventories list what evidence is available, and often other contextual information needed for making decisions, but do not synthesize the evidence or present summaries or conclusions. They are generally systematic and comprehensive; therefore, can provide a useful first step for decisions about coverage or purchase, in particular whether further research is warranted.
- Rapid responses evaluate the literature to present the end-user with an answer based on the best available evidence (usually guidelines or systematic reviews), but do not attempt to formally synthesize the evidence into a conclusion. This type of product was more likely to describe clinicians among end-users.
- “True” rapid reviews perform a synthesis (qualitative, quantitative, or both) to provide the end-user with a conclusive answer about the direction of evidence and possibly the strength of the evidence. The conclusion may be hedged, but it is still a synthesized statement that could be compared with a systematic review. They are generally able to meet time constraints by limiting the scope, are somewhat less comprehensive in their data sources, use fewer quality controls, and the synthesis is usually qualitative.
- Finally, automated approaches are a new and intriguing approach to providing rapid evidence support, and worth future study.

## Moving Beyond Methods

Through our interviews with a large number of organizations who develop rapid products it became clear that the conduct of a rapid product in most cases is not simply a “mini-systematic review with corners cut” but that the very essence of developing rapid products differs from that of systematic reviews. One of the biggest differences between rapid products and traditional systematic reviews is the relationship with the stakeholder. Rapid products are often conducted to help a specific end-user make a specific decision in an identified timeframe; therefore, the reviewers needs to make decisions about what they can provide in the time allowed. This in large part explains the broad portfolio of rapid products and reporting formats. The timeframe also explains the choice of some groups to rely heavily on prior systematic reviews. Maintaining a highly skilled staff is critical to rapid response groups who need products in a short timeframe and understand the type of products that might meet the needs of the decision maker. Finally, few and/or narrow questions were also a necessary approach, focusing on new or emerging technologies or single interventions within a narrow population.

Based on our review of the literature, there is almost no empiric evidence comparing results of rapid products with systematic reviews. For the most part, the research represents indirect evidence about whether truncating methods have an impact on results and conclusions. One report that provided direct evidence suggests that there may not be any impact; however, this report was in the context of HTAs and focused exclusively on surgical interventions often early in their implementation. The systematic and rigorous approach implied in the use of the term “review” cannot clearly be completely fulfilled in a more rapid process, but little is known about the impact of truncated methods. Thus, shorter may not always be better, or even as good, but currently available information does not tell us if and when to be concerned. For example, previous research has suggested that lack of quality or risk of bias assessment may result in over-representation of or inappropriate emphasis on poor quality research.17 Further, previous research has raised the concern that rapid products may not comprehensively address safety issues.14 The issue of safety assessment did not specifically arise during the Key Informant interviews; however, we found that often rapid products were limited in the scope of the question(s) and the number of outcomes examined, often with a focus on efficacy outcomes. Closer examination of the appropriateness of rapid products for issues of safety is needed. Finally, many rapid products rely on qualitative synthesis which can be more challenging than quantitative synthesis in terms of determining effectiveness and assessing heterogeneity; moreover, many approaches to qualitative synthesis rely on vote counting methods which are not recommended within systematic review standards.

In summary, rapid products have tremendous variation in methodological practices; however, what appears to tie them together is the close relationship with the end-user to generate an evidence base that meets their decision-making needs within a limited amount of time. To date, there is little empiric evidence regarding the validity of results and conclusions based on rapid approaches to reviewing the literature and this was an expressed concern of the interviewees.

## What Was Known and What This Paper Adds

Our findings are consistent with previous reviews showing that rapid review methods vary greatly, as do their definitions and applications. For example, a 2010 systematic review of “rapid reviews” examined 45 methodological articles and 25 exemplars of rapid review methods and found many subtle differences among terms used to denote a more accelerated production process (e.g., rapid, ultra rapid, succinctly timed) for a type of product (e.g., technology assessment, systematic review, evidence assessment). These differences were magnified when considering the associated timeframes which, although not consistently reported, ranged from one to nine months, and overlapped in the time required for or even as long as some traditional systematic reviews and more comprehensive evidence synthesis products (e.g., technology assessments). Also consistent with our findings, the earlier systematic review found that rapid reviews varied in their methodological approaches and how closely these adhered to current standards for systematic reviews.11 We showed that this methodological variation was related to production time with more standard methods incorporated where more time was available. As we did not review the actual rapid products, we did not assess quality of reporting. Previous reviews and overviews on rapid reviews also raise concerns about potential impacts on the validity of information resulting from truncated methods or timelines.9-11,24 Our search for and review of empirical evidence showed a substantial gap in this area.

The 12 previous reviews we identified that examined different rapid products do not support substituting any form of rapid product for a standard systematic review, although investigators recognize the value of rapid products for answering narrow efficacy or effectiveness questions within a shorter timeframe and with fewer resources. Our findings showed that often the rapid products are geared towards narrow questions, and that producers take time to appropriately scope the topic in order to meet the constrained timeframes. Previous reviews document methods for shortening the length to complete rapid products, including searching fewer sources, excluding grey literature, applying search filters, and employing only one reviewer for title/abstract reviewing or data extraction. These reviews also found that meta-analyses were rarely conducted in rapid products, although recommendations for producers of rapid products include meta-analyses as worthwhile additions to these evidence summaries. Previous reviewers noted that caution is needed when interpreting evidence when quality assessment has not been done, and recommended enhanced transparency in reporting methods used for the rapid product.

Our data collection and analysis build on the findings of this previous work in three important ways. First, as described above, we recognized early on that there was substantial variability across the rapid products and that “rapid reviews” does not reflect a specific methodological approach. As such, we sought to classify these products in a meaningful way. We found a natural grouping according to the extent of synthesis done as part of the report and classified accordingly as inventories (no synthesis), rapid responses (some organization and evaluation of the literature), and rapid reviews (synthesis—qualitative, quantitative, or both). Second, we analyzed the methods by production time showing not simply variation in approaches but instead a systematic increase in comprehensiveness and incorporation of more standard review methods with increased production time. Third, and our unique contribution, was the interviews with producers of rapid products and identification of items beyond the technical aspects of producing reports that seemed to underpin the essence of rapid products. The key factors were the relationship with the end-user and the focus on producing evidence to meet a very specific decisionmaking need. In this context, rapid products may be a reasonable substitute for standard systematic reviews, so long as the end-user understands any potential caveats arising from the methods employed. Rapid products may be a reasonable alternative to standard systematic reviews in the following cases: urgent decisions, decisions not likely to have negative health consequences for large populations, decisions that can be easily changed if new information leads to a change in the appraisal, decisions about low risk interventions, and decisions about low cost interventions. The utility and appropriateness of rapid methods for safety outcomes needs further evaluation. A further consideration is opportunity costs, e.g., having rapid products on multiple questions of interest to the end-user versus standard systematic reviews for just one or two. We also identified key aspects of the organizations that allow them to produce rapid products, including the capacity to respond quickly to end-user requests and mobilize a highly trained and experienced staff. Our Key Informant interviews reinforced the findings of previous studies highlighting the need for health care researchers to focus on the informational needs and preferences of their target audiences.25 This focus ensures the conduct of relevant and timely research that decision makers can directly apply to their local contexts.25,26

## Pragmatic Considerations

Based on our review of the literature and interviews with Key Informants with extensive experience developing rapid products, we offer the following items that should be considered by a group or organization prior to implementing a program that offers reports in a limited timeframe. We believe that many of these factors need to be in place for an effective rapid response program.

- Context: Many organizations reported producing reports for very specific decisionmaking needs in very specific circumstances. The evidence needed to inform decisions in this context is quite different from a systematic review that is intended to be used by multiple stakeholders (who are not necessarily all known or identified during preparation of the review).
- Relationship with the end-user: Most organizations described a continuous and close relationship with a specific end-user involving iterative feedback throughout the work to ensure the product would meet the end-user's needs. This is in contrast to a more “arms-length” relationship with end-users who may be engaged at specific time points during a systematic review, but who may also be separated during certain phases to reduce bias.
- Reliance on secondary sources: Many organizations relied on existing systematic reviews or HTA reports. Methods need to be in place, and acceptable to the end-users, to synthesize and interpret evidence from existing reviews.
- Capacity: Most organizations had extensive experience producing rapid products and had a highly skilled staff that either also prepared standard systematic reviews or HTA reports, or had experience doing so. The ability to mobilize skilled staff quickly was critical for a timely response, efficient back-and-forth communications to refine the questions and scope, and an expedited product.
- Scope: Many organizations restricted the scope of the review to meet reduced timelines. Often questions focused on single interventions, single comparisons, specific populations, or specific outcomes. Many focused on new or emerging technologies for which little evidence was available resulting in the ability to review evidence quickly.
- Methods: The reality of rapid products is that they are not necessarily as comprehensive as systematic reviews and do not meet all the accepted methodological standards. The producers and users need to be able to accept some modification to the methods in order to meet constrained timelines. Interestingly, some interviewees commented that individuals who came from a systematic review background often had a harder time making methodological concessions in the interests of efficiency.
- Reporting and caveats: Pragmatic decisions to limit a review will lead to a tradeoff between preparation of a review that is timely and useful with potentially less accurate findings, and one that is comprehensive and as accurate as possible.27 Central to the rigor of the systematic review approach is transparency. As with any systematic review, the methodological approaches and accompanying justifications need to be clearly reported and also reflected on in terms of potential bias and shortcomings in the review conclusions, as well as the potential value of a more comprehensive review.27 Finally, the issue of protocols and pre-specified methods was not specifically addressed in this work but warrants consideration in the context of rapid products in the interest of transparency.

## Strengths and Limitations

Our combined approach of reviewing the literature and conducting Key Informant interviews provided a rich source of information on rapid products, methods, and organizational perspectives. We analyzed and classified rapid products in unique ways that complement existing literature. We identified a select set of Key Informants from a number of well-known organizations that produce rapid products; however, the results may not be representative of all organizations or groups that produce rapid products. We also identified products through our literature review; however, programs captured in this manner may or may not be currently active. We sought to be comprehensive and consistent in the information gathered through the interviews and literature in order to accurately describe all rapid products; however, sometimes the information was limited in the literature and not all interviewees responded to our queries to confirm details. We gathered information on the overall timeframes for completion of rapid review products; however, we do not have detailed information on the total work hours involved in preparing different types of reviews. Further, we do not know whether the timeframes for production reflect real or artificial timelines (i.e., a report is produced in 2 weeks but is there an actual decision waiting to be made at the end of those 2 weeks). We found very limited data on the validity of rapid products and this should be a priority for future research. Of specific interest is the validity of rapid products for assessing safety outcomes. A point that arose while drafting the report is the issue of durability of the findings of rapid products. The issue of updating for standard systematic reviews has received much attention among methodologists and producers of systematic reviews and warrants consideration within the field of rapid products.

## Future Directions

The work reported in this paper has helped us understand the approaches undertaken in the production of rapid products, and perspectives from relevant organizations. Many of these organizations have well-established rapid response programs that have existed for years. This fact underscores the value and role of rapid products in some situations and for particular end-users. A next important step is to assess the end-user perspectives on different rapid products, and the acceptability of different approaches to support their decision-making needs. To this end, we plan to conduct additional work gathering feedback from different end-users on concrete rapid product scenarios. These will help highlight the most important differences and trade-offs between rapid products and standard systematic reviews, and help guide decision making about when and where particular products would be helpful. Our results showing variation in rapid products by both timeframe and extent of synthesis will help us establish an interview guide to assess the relative importance of these factors in meeting end-user needs. Further, we will be able to ascertain how closely the timeframes and products are tied to actual decision making (e.g., is a report produced in 2 weeks used to make a decision at the end of those 2 weeks). Finally, we plan to address the issue of updating or “durability” of the products and whether this is an issue or concern for end-users.

We searched for evidence that compared the results and conclusions of rapid products with those from standard systematic reviews, and found little empirical evidence. We did not specifically search for empirical evidence on different aspects and/or methods that may be modified to conduct a review more rapidly (e.g., restricted number of databases searched, recursive approach to searching, restrictions on study designs eligible for inclusion, limited data extraction, lack of quality or risk of bias assessment, reduced quality control mechanism [i.e., dual study selection and data extraction], analytic approaches). However, this paper provides a detailed examination of the granular differences between products that are generated within different timeframes and offers a structure for detailed empirical investigations of how each of these methods impact final results and conclusions, and inform decisionmaking.

Finally, given that most reviews have found heterogeneity across rapid products, it might be helpful in the future to apply functional groupings such as the typology used in this paper (Inventory, Response, Review, and Algorithm). In addition to allowing more conclusive analysis, this kind of framework could also be useful for evolving best practices—since best practices will clearly need to differ based on level of synthesis—and also for any empirical work either comparing rapid products with systematic reviews, or testing the validity of rapid methods.