# Conclusions

There is extensive variability in products commonly labelled “rapid reviews.” These products vary on two important dimensions which are captured by the term “rapid review:” the timeframe for completion and extent of review or synthesis. Our review of these products resulted in a classification according to the level of synthesis that we feel is a useful contribution to this field: inventories (no synthesis), rapid responses (some organization and evaluation of the literature), rapid reviews (synthesis—qualitative, quantitative, or both), and automated approaches (computer-generated responses to user-defined queries). We found a systematic increase in comprehensiveness and incorporation of more standard review methods with increased production time. There are a number of dimensions beyond the technical aspects of producing reviews that seemed to underpin the essence of rapid products, including the relationship with the end-user and the focus on producing evidence to meet a specific decision-making need. The well-established and longstanding programs among organizations that produce rapid products underscore the value of these products for end-users as a basis for decision making. More in-depth evaluation of end-user perspectives on rapid products will complement our findings and together will provide a more complete set of considerations for those interested in establishing a rapid response program or producing rapid reviews.