# Types of Rapid Review Products Described by Key Informants

This appendix provides additional information that was gathered from the Key Informant interviews. Some of this content overlaps with the information that is presented in the results' section of the main report based on the combined analysis of the Key Informant interviews and the literature.

Interviewees described several rapid review products, some completed within days (Table E-1). Tables E1-4 below describe the products and the names that Key Informants used to describe them according to the timeframe in which they were produced. Most organizations appeared to have started with a product that was produced in several months. Because rapid reviewers have a strong relationship with a particular requestor, they often spoke about asking the requestor when they needed to make the decision, and then the reviewer would work back to present what could be done in that timeframe and explore whether this would be helpful. Over time, various products were developed in the back-and-forth conversation between reviewers and requestors ranging from products that were completed within days to months.

Table E-1 Products completed in days (based on Key Informant interviews)

Name of product | Timeframe | Report Style | Process
Reference List | 1-7 days | List of available evidence, sorted by study design. | Work directly with requestor to determine what is needed. Search major databases (Embase, PubMed, Medline, Cochrane) and other HTA agencies.
Scoping Review | 3-5 days | List of available evidence. | Patient submitted appeal for single technology or intervention. Search TRIP, PubMed, Cochrane. Send list to committee for decisionmaking.
Rapid Review | 3 days | Narrative summary of evidence with recommendation. | Receive questions from health plans and work directly with nominator. Search Medline, Embase and summarize available evidence. Includes quality appraisal and grading.
Rapid Review | 7 days or less | 1 page narrative summary of evidence. | Work directly with clinicians who submit questions. Search first for existing reviews (TRIP, Cochrane) and go to primary evidence if necessary.

Table E-2 Products primarily using existing reviews (based on Key Informant interviews)

Name of product | Timeframe | Report Style | Process
Rapid Review | 1 week or less | 1 page narrative summary of evidence. | Work directly with clinicians who submit questions. Search first for existing reviews (TRIP, Cochrane) and go to primary evidence if necessary.
Evidence Briefing | 1 month | Narrative summary of existing evidence. | Work directly with requestors to determine questions/timeframe. Search their own database (DARE) which has quality rated existing reviews. If no reviews are found, do not search primary evidence but tell requestor that no existing reviews are available.

Table E-3 Landscape of rapid products by timeframe (based on Key Informant interviews)

Timeframe | Landscape of reports
< 7 days | There are 4 different reports, the scopes of these were varied but were fairly narrow (single intervention, evaluating effectiveness only, single technology). The styles of these reports varied from a reference list to presenting the scope of the evidence to narratives. Only one included internal review, one study considered feedback on the website as external review. None of the reports performed quantitative analysis, though one did conduct qualitative analysis. One of the four provided recommendations. The number of people working on the reports ranged from 2-10. One type relied on existing SRs.
1-2 weeks | Two reports were conducted in 1 to 2 weeks. Dual review was not conducted for either of these, nor did they rely solely on existing SRs. Neither report conducted dual extraction nor did they conduct quality appraisal, and only one conducted a full text review. Internal or external review was not conducted and no recommendations were provided.
1-2 months | Sixteen reports were conducted and most of these were classified as Rapid Reviews. Others were Brief Reports; Rapid Summary; Evidence Briefing; Medical Technology Assessment; Literature Summary; Health Technology Assessment; Evidence Inventory; Evidence-based Briefs and Evidence Advisory. The purpose for most of these was to be used in health system decisions. Very few of the reports conducted dual study selection. Some used existing SRs but not as the sole source of evidence. Almost all of the data extraction was conducted by just one person, most conducted quality appraisal for primary studies as well as SRs using AMSTAR. Some conducted strength of evidence assessments and the most used method was GRADE. Most of these reports had a structured format, many included evidence tables and a narrative synthesis. Few reports did not conduct any sort of internal or external review; most included external review. Most of the reports conducted qualitative synthesis, and some conducted both qualitative and quantitative synthesis. Very few of the reports provided guidance. 1-10 people could have worked on any given report.
3-6 months | Eight reports were conducted in 3-6 months most of which are referred to as rapid reviews. Literature selection was mostly done by one person. All of these reviews included existing SRs, not as sole data source. Most conducted data extraction by one person, quality appraisal and SOE. Most of the reports had a structured format and the styles of the reports varied but most included external review. None conducted a quantitative analysis, some did a qualitative analysis, and none of the reports provided guidance.
12-18 months | One report was conducted in 12-18 months. This is a single technology appraisal that produces national guidance to inform drug funding. The reviewers did not conduct a literature search as this was already done by the manufacturer. The manufacturer provided most of the report pieces (search, template, synthesis) and the organization acted as a dual reviewer in the process.

Table E-4 End-users of rapid review products by timeframe

Timeframe | End-users of rapid review products
< 7 days | Clinicians, health plan, national health system decisionmakers, patients, regional health system decisionmakers
1-3 weeks | Health systems, hospitals, payers, public health consultants
1-3 months | “Clinical commissioning groups”, clinicians, guideline development organizations, health plans, healthcare systems, hospitals, national health system decisionmakers, regional health system decisionmakers
3-6 months | Government organizations, health systems, hospitals, national health system decisionmakers, regional health system decisionmakers, universities
12-18 months | Health system decisionmakers, national policy decisionmakers

Interviewees also described several rapid review products that use existing reviews as the primary or sole source of evidence. These products were narrative summaries of the existing evidence. Details of these products are outlined in Table E-2.

Table E-3 provides an overview of the different rapid products and Table E-4 provides a list of the end-users by timeframe; the information in these tables is based on the Key Informant interviews.