# Characteristics of Rapid Products

This appendix provides four summary tables of rapid products according to: (1) scope and purpose, (2) comprehensiveness, (3) methodological rigor and quality control, and (4) approach to analysis, synthesis, and conclusions. There are 36 products produced by 20 organizations; these are ordered by classification and timeframe.

Table D-1 Scope, end-user, and purpose of different rapid review products

* | Classification | Timeframe | Scope | | | | End-user | Purpose
* | Classification | Timeframe | Limit to single comparison | Limit to emerging technology | Limit number of questions | Limit number of studies | End-user | Purpose
E1 | Inventory | 3-5 days | Y | Y | Y | N | Hosp Admin, Payers | Give user a picture of available evidence and regulatory issues
A1 | Inventory | 5-10 days | N | N | U | N | Health system admin, clinicians | Allow user to do own research
L1 | Inventory | 5-15 days | Y | N | Y | N | Hosp Admin, Payers, Policy makers | Payers-coverage, Hospital admin for purchase, policy makers for both
R1 | Inventory | 1-2 weeks | Y | N | Y | N | Health system administrators, policy makers | Assess need for future research in support of purchase and coverage
I1 | Inventory | <4 weeks | N | N | N | N | Hospital admin, clinicians | Assess need for future research
G1 | Inventory | 1-2 months | N | N | N | N | Admin | Research prioritization
C1 | Rapid response | 3-5 days | Y | Y | Y | [Y] | Payer | Coverage
D1 | Rapid response | <1 week (could be <1 day) | Y | N | Y | N | Clinician | Clinical decisions
A2 | Rapid response | 15 days | Variable | N | Y | N | Policy maker | U
D3 | Rapid response | 2-4 weeks | N | N | Y | N | Policy maker | Coverage
F1 | Rapid response | 4 weeks | N | N | Y | N | Policy maker | Purchase
U1 | Rapid response | 1 month (minimum) | N | U | U | U | Service providers | Designing care delivery
T1 | Rapid response | 2-6 weeks | N | N | N | N | Clinicians | Clinical decisions
I2 | Rapid response | 4-8 weeks | Variable | N | Y | Y | Hosp admin, clinicians | Purchase, clinical decisions
R2 | Rapid response | 1-3 months | Y | N | Y | Variable | Policy makers | U
O1 | Rapid response | 10-12 weeks | Variable | N | U | U | Research inst, govt, manufacturers | Background
B1 | Rapid review | 3 days | Y | Y | N | [Y] | Payer | coverage
E2 | Rapid review | 4 weeks | N | Y | Y | [Y] | Hospital admin, payer | coverage
H1 | Rapid review | 1 month | Y | Y | N | [Y] | Hospital Admin | purchase
A3 | Rapid review | 30 days | Y | N | Y | [Y] | Policy, admin | U
A4 | Rapid review | 30 days | Y | N | Y | [Y] | Policy, admin | U
J1 | Rapid review | 4-6 weeks (up to 16 max) | N | Y | N | N | Policy maker, hosp admin | Purchase, policy
C2 | Rapid review | 4-8 weeks (up to 10) | Y | Y | N | Y | Hosp admin | Purchase/deployment
S1 | Rapid review | 2 person-months | Y | Y | U | U | Hospital admin | purchase
I3 | Rapid review | 8-12 weeks | Y | N | Y | [Y] | Hospital admin, clinicians | Purchase, practice decision
L2 | Rapid review | 2-4 months | Y | N | Y | Y | Payer | coverage
L3 | Rapid review | 2-4 months | Y | Y | Y | Y | Payer and hospital admin | Coverage, purchase
G2 | Rapid review | 3-4 months | N | N | Y | [Y] | Health system admin | U
O2 | Rapid review | 3-4 months | Variable | N | U | U | Research inst, govt, industry | Policy, coverage, other
P1 | Rapid review | 3-4 months | N | N | Y | [Y] | Policy maker, hosp admin | U
R3 | Rapid review | 3-6 months | Y | N | Variable | [Y] | U | U
M1 | Rapid review | 3-8 months | Y | N | Y | [Y] | Payer | coverage
M2 | Rapid review | 3-6 months (NS) | Y | N | Y | [Y] | Payer | coverage
N1 | Rapid review | 3-6 months (NS) | N | Y | Y | [Y] | Policy maker, hosp admin | Purchase, coverage
D2 | Algorithm | 5 minutes | Y | N | Y | N | Clinicians, Policy makers | U
K1 | Algorithm | 1-6 weeks | N | N | N | Around 30 | U | Allow user to do own research

* working code used for internal purposes

[Y]: No set limit for studies, but other aspects of scope (comparisons, questions, outcomes) adjusted to reduce the number of studies to a manageable number for the timeframe.

Note: If this aspect was described as sometimes limited, this was counted as a “Yes”

U = unknown

Table D-2 Comprehensiveness of different rapid review products

* | Classification | Timeframe | Number of electronic databases | Grey literature searches | Language restrictions | Date restrictions | Other search restrictions^†^ | Use Existing SRs and/or HTAs | Use primary studies
E1 | Inventory | 3-5 days | 2 | Yes | English | Sometimes | Sometimes | No | Yes
A1 | Inventory | 5-10 days | 1+ | Limited | Yes | Yes | Yes | Yes | Yes
L1 | Inventory | 5-15 days | 1+ | Yes | Yes | Yes | No | Yes | Yes
R1 | Inventory | 1-2 weeks | U | Limited | Yes | Yes | U | U | Yes
I1 | Inventory | <4 weeks | 4+ | Yes | Yes | Sometimes | Sometimes | Yes | [Yes]
G1 | Inventory | 1-2 months | U | U | U | U | U | U | U
C1 | Rapid response | 3-5 days | 3 | U | U | U | U | U | U
D1 | Rapid response | <1 week (could be <1 day) | 1+ | No | U | No | U | Yes | [Yes]
A2 | Rapid response | 15 days | 1+ | Limited | Yes | Yes | Yes | Yes | [Yes]
D3 | Rapid response | 2-4 weeks | Up to 4 | No | U | No | No | Yes | [Yes]
F1 | Rapid response | 4 weeks | 2 | Yes | Yes | U | U | Yes | No
U1 | Rapid response | 1 month (minimum) | 3+ | Yes | Yes | Sometimes | No | Yes | Yes
T1 | Rapid response | 2-6 weeks | 4 | Yes | U | U | Sometimes | Yes | Yes
I2 | Rapid response | 4-8 weeks | 4 | Yes | Yes | Sometimes | Sometimes | Yes | No
R2 | Rapid response | 1-3 months | 2+ | Limited | U | Yes | U | Yes | Yes
O1 | Rapid response | 10-12 weeks | 3 | Yes | Yes | Yes | U | Yes | [Yes]
B1 | Rapid review | 3 days | 2 | Yes | U | U | U | U | Yes
E2 | Rapid review | 4 weeks | 2 | Yes | U | Sometimes | No | No | Yes
H1 | Rapid review | 1 month | 5 | U | Yes | Yes | U | Yes | [Yes]
A3 | Rapid review | 30 days | 1+ | Limited | Yes | Yes | U | Yes | [Yes]
A4 | Rapid review | 30 days | 4 | Limited | Yes | Yes | U | Yes | [Yes]
J1 | Rapid review | 4-6 weeks (up to 16) | 2-3 | U | U | U | U | Yes | [Yes]
C2 | Rapid review | 4-8 weeks (up to 10) | 4 | Yes | U | Sometimes | U | Yes | Yes
S1 | Rapid review | 2 person-months | U | U | U | U | U | U | Yes
I3 | Rapid review | 8-12 weeks | 4+ | Yes | Yes | Sometimes | Sometimes | Yes | [Yes]
L2 | Rapid review | 2-4 months | 4 | Yes | Yes | Sometimes | Yes | [No] | Yes
L3 | Rapid review | 2-4 months | 5 | Yes | Yes | U | Sometimes | [No] | Yes
G2 | Rapid review | 3-4 months | U | Yes | Yes | No | No | Yes | [Yes]
O2 | Rapid review | 3-4 months | 3 | Yes | Yes | Yes | No | [No] | Yes
P1 | Rapid review | 3-4 months | Variable | Sometimes | Yes | Sometimes | U | Yes | Yes
R3 | Rapid review | 3-6 months | 2+ | Limited | U | Yes | U | Yes | Yes
M1 | Rapid review | 3-8 months^‡^ | 2 | Yes | Yes | U | Yes | Ye | [Yes]
M2 | Rapid review | 3-6 months (NS) | 2 | Yes | Yes | U | Yes | Yes | No
N1 | Rapid review | 3-6 months (NS) | U | No | Yes | Sometimes | Yes | Yes | Yes
D2 | Algorithm | 5 minutes | 1 | No | U | No | No | No | Yes
K1 | Algorithm | 1-6 weeks | 1+ | Yes | No | No | No | [No] | Yes

* working code used for internal purposes

† these additional restrictions could include limiting studies based on geographic region, setting of care, minimum number of patients, duration

‡ small (3 months), medium (6 months), large (8 months)

[Yes] – only use primary studies if no SRs or HTAs

[No] – not the focus

NS = not specified; interviewee did not provide more detail on timeframe

U = unknown

Table D-3 Methodological rigor and quality control of different rapid review products

* | Classification | Timeframe | Full text review | Limited data elements extracted | Dual study selection | Dual data extraction | Internal review | External review
E1 | Inventory | 3-5 days | No | Yes | No | No | No | No
A1 | Inventory | 5-10 days | No | N/A | No | N/A | Yes | No
L1 | Inventory | 5-15 days | No | Yes | No | No | Yes | No
R1 | Inventory | 1-2 weeks | No | N/A | No | No | No | No
I1 | Inventory | <4 weeks | Yes | Yes | No | No | Yes | No
G1 | Inventory | 1-2 months | No | N/A | No | No | No | No
C1 | Rapid response | 3-5 days | U | U | No | No | U | U
D1 | Rapid response | <1 week (could be <1 day) | No | Yes | No | No | No | No
A2 | Rapid response | 15 days | No | N/A | No | No | Yes | No
D3 | Rapid response | 2-4 weeks | No | Yes | No | No | No | No
F1 | Rapid response | 4 weeks | Yes | Yes | U | [Yes] | Yes | Sometimes
U1 | Rapid response | 1 month (minimum) | U | N/A | U | U | Sometimes | No
T1 | Rapid response | 2-6 weeks | Yes | Yes | No | No | U | U
I2 | Rapid response | 4-8 weeks | Yes | Yes | No | No | Yes | No
R2 | Rapid response | 1-3 months | Yes | Yes | No | No | U | No
O1 | Rapid response | 10-12 weeks | Yes | N/A | No | N/A | Yes | No
B1 | Rapid review | 3 days | Yes | N/A | No | No | Yes | No
E2 | Rapid review | 4 weeks | Yes | Yes | No | No | Yes | No
H1 | Rapid review | 1 month | Yes | U | No | No | U | U
A3 | Rapid review | 30 days | Yes | Yes | No | No | Yes | No
A4 | Rapid review | 30 days | Yes | Yes | No | No | Yes | Yes
J1 | Rapid review | 4-6 weeks (up to 16 max) | Yes | Yes | Yes | [Yes] | Yes | Yes
C2 | Rapid review | 4-8 weeks (up to 10) | Yes | Yes | No | No | No | No
S1 | Rapid review | 2 person-months | U | U | U | U | U | Yes
I3 | Rapid review | 8-12 weeks | Yes | Yes | No | No | Yes | No
L2 | Rapid review | 2-4 months | Yes | No | No | No | U | Yes
L3 | Rapid review | 2-4 months | Yes | Yes | Yes | No | Yes | Yes
G2 | Rapid review | 3-4 months | Yes | Yes | Yes | [Yes] | Yes | Yes
O2 | Rapid review | 3-4 months | Yes | Yes | Sometimes | Sometimes | Yes | Sometimes
P1 | Rapid review | 3-4 months | Sometimes | Yes | U | U | Yes | No
R3 | Rapid review | 3-6 months | U | U | No | No | U | Yes
M1 | Rapid review | 3-8 months | Yes | Yes | Partial^†^ | [Yes] | U | Yes
M2 | Rapid review | 3-6 months (NS) | Yes | Yes | Partial^†^ | [Yes] | U | Yes
N1 | Rapid review | 3-6 months (NS) | Yes | Sometimes | Yes | [Yes] | Yes | No
D2 | Algorithm | 5 minutes | No | Yes | No | No | No | No
K1 | Algorithm | 1-6 weeks | Yes | No | Yes | Yes | Yes | Sometimes

* working code used for internal purposes;

† second person reviews excludes at title/abstract stage, dual review of full text

N/A – no data extraction

[Yes] – one with verification

NS = not specified; interviewee did not provide more detail on timeframe

Table D-4 Approach to analysis, synthesis, and conclusions in different rapid review products

* | Classification | Timeframe | Quality/ROB appraisal | SOE/GRADE conducted | Qualitative analysis | Quantitative analysis | Conclusions
E1 | Inventory | 3-5 days | No | No | No | No | No
A1 | Inventory | 5-10 days | No | No | No | No | Key messages
L1 | Inventory | 5-15 days | No | No | No | No | Opinion
R1 | Inventory | 1-2 weeks | No | No | No | No | No
I1 | Inventory | <4 weeks | No | No | No | No | No
G1 | Inventory | 1-2 months | No | No | No | No | No
C1 | Rapid response | 3-5 days | No | No | No | No | No
D1 | Rapid response | <1 week (could be <1 day) | No | No | No | No | No
A2 | Rapid response | 15 days | No | No | No | No | Summary of best evidence
D3 | Rapid response | 2-4 weeks | No | No | No | No | Report what studies concluded - no explicit review conclusion
F1 | Rapid response | 4 weeks | Yes | Sometimes | No | No | Yes
U1 | Rapid response | 1 month (minimum) | No | U | No | No | Key messages
T1 | Rapid response | 2-6 weeks | No | No | Yes | No | No
I2 | Rapid response | 4-8 weeks | Yes | No | Yes | No | Summary of what best guidelines, protocols, and systematic reviews say
R2 | Rapid response | 1-3 months | No | No | No | No | Summary of best evidence
O1 | Rapid response | 10-12 weeks | No | No | Yes | No | [Yes]
B1 | Rapid review | 3 days | Yes | Yes | Yes | No | Yes
E2 | Rapid review | 4 weeks | Yes | Yes | Yes | No | Yes
H1 | Rapid review | 1 month | U | Yes | Yes | No | Yes
A3 | Rapid review | 30 days | Yes | No | Yes | No | Yes
A4 | Rapid review | 30 days | Yes | No | Yes | No | Yes
J1 | Rapid review | 4-6 weeks (up to 16 max) | Yes | [No] | Yes | No | Yes
C2 | Rapid review | 4-8 weeks (up to 10) | Yes | Yes | Yes | No | Yes
S1 | Rapid review | 2 person-months | Yes | No | Yes | Yes | No
I3 | Rapid review | 8-12 weeks | Yes | Yes | Yes | No | No
L2 | Rapid review | 2-4 months | Yes | Yes | Yes | Yes | [Yes]
L3 | Rapid review | 2-4 months | Yes | No | Yes | No | [Yes]
G2 | Rapid review | 3-4 months | Yes | Yes | Yes | Yes | Yes
O2 | Rapid review | 3-4 months | Yes | U | Yes | No | Yes
P1 | Rapid review | 3-4 months | Sometimes | Sometimes | Sometimes | Sometimes | Opinion
R3 | Rapid review | 3-6 months | No | No | Yes | No | Yes
M1 | Rapid review | 3-8 months | Yes | Yes | Yes | Yes | Yes
M2 | Rapid review | 3-6 months (NS) | Yes | Yes | Yes | Yes | [Yes]
N1 | Rapid review | 3-6 months (NS) | Yes | Yes | Yes | Yes | Yes
D2 | Algorithm | 5 minutes | No | No | Yes | Yes | Yes
K1 | Algorithm | 1-6 weeks | Yes | Yes | No | No | No

* working code used for internal purposes

[No] – under consideration

[Yes] - yes conclusions, no recommendations

NS = not specified; interviewee did not provide more detail on timeframe

U = unknown