# Flow of Studies from the Literature Review

Figure 1 Search flow diagram

A figure titled ‘Figure 1 Search flow diagram’. This figure outlines the results from the literature search, abstract and full-text review. The first box reads “Search results after duplicates removed: 468”. An arrow points downward to a second box reading “116 Included”. An arrow to the right leads to another box reading “352 Excluded”. An arrow from the second box points downward to a third box reading “143 full-text articles reviewed”. A box to the left of this box reads “27 articles from workgroup and key informants” with an arrow pointing towards the third box. An arrow points downward from the third box to a fourth box reading “53 included articles”. An arrow points to the right to another box reading “90 Excluded”. An arrow points downward from the fourth box to a set of four arrows each pointing to a separate box. From left to right the boxes read “Background: 8”, “Empiric data: 5”, “Review of rapid review types: 12”, and “Rapid review methods: 30”.