# Interview Guide

## Introduction

The overall mission of the Agency for Healthcare Research and Quality's (AHRQ) Effective Health Care (EHC) Program is to provide evidence-based information to health care stakeholders that is relevant to their needs, timely, objective, scientifically rigorous in construct, and developed and presented with transparency. In the production of systematic reviews, we aim to answer questions about effectiveness of interventions and average population effects. We are aware that for certain conditions and behavioral interventions, these questions may miss important issues.

AHRQ engages stakeholders in all facets of their research enterprise, including the producing of systematic reviews, with the goals of ensuring that research findings reflect the needs of diverse users, are relevant to their unique challenges, and are applicable in real-world situations.

## Purpose of the Stakeholder Interview

The goal of our project is to understand methods you have used, challenges you and others frequently encounter, and your advice on producing rapid reviews.

We are very interested in learning from your experience.

There are not right or wrong answers, so please feel free to share your thoughts openly.

We would welcome any materials that you would like to share with us either before or after the interview session. Please send any materials to Johanna.anderson2@va.gov.

## Ground Rules for the Stakeholder Interview

The interview will be tape recorded, transcribed, and analyzed for overarching themes.

Although the report may list individuals who were interviewed, answers will not be identifiable to individuals or specific organizations.

You may refrain from answering any questions and are welcome to end the interview at any time.

## Interview Guide

1. How would you define a rapid review (in regards to time, scope, etc.)?
2. How long have you been doing rapid reviews?
3. Who do you produce rapid reviews for?
  What is your organizational structure for how you produce rapid reviews (i.e., staffing, organizational capacity)?
  a. Who does your rapid reviews? What types of skills/expertise do they have?
4. How do you determine which instances require a rapid review?
5. What is a typical timeline and scope? Representative timeline and scope?
6. Can you describe the methods used to produce a rapid review for each part of the review process (scoping, searching, extraction, synthesis, peer review, conflict of interest)?
  a. In what ways do you gain efficiency in the rapid review process?
  b. Are there any technologies or other tools that help you gain efficiency in the process?
7. Do you have any formal guidance documents that you use internally? Have you published on your methods?
8. What do your rapid review products look like (how long do they take, how many pages, etc.)?
9. What would you say are the advantages of the methods you used to make the process a rapid review? What are the disadvantages, if any?
10. What has been your experience with end-users and how they accept rapid review methods?
11. Would you be willing to share any examples of your work?