# Search Strategy

32Ovid MEDLINE(R) 1946 to October Week 5 2013

Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations November 6, 2013

Searched: November 6, 2013

1 | ((rapid or mini or pragmatic or targeted or focused or brief) adj2 (((systematic or evidence or data or knowledge) adj2 (review* or synthes*)) or HTA or health technology assessment*)).ti,ab. | 318
2 | ((rapid or pragmatic) adj2 (review* or HTA or health technology assessment* or evidence assessment*)).ti,ab. | 381
3 | 1 or 2 | 656
4 | 3 not animals/ | 572
5 | remove duplicates from 4 | 519
6 | limit 5 to (english language and yr=“2000 -Current”) | 409

Ovid EBM Reviews - Cochrane Methodology Register 3rd Quarter 2012

Searched: November 7, 2013

1 | ((rapid or mini or pragmatic or targeted or focused or brief) adj2 (((systematic or evidence or data or knowledge) adj2 (review* or synthes*)) or HTA or health technology assessment*)).ti,ab. | 22
2 | (rapid adj2 review*).ti,ab. | 15
3 | 1 or 2 | 32

SRC Methods Library

Searched: October 21, 2013

Descriptor search: systematic reviews – rapid

27 records retrieved