# What To Assess and How To Interpret Measures of Functional Status and Health-Related Quality of Life

## Conceptual Framework

An intervention is grounded in some conceptual framework about how the intervention would work and what dimensions of health status it would impact. The systematic reviewer must examine the conceptual framework of the original work to determine if the study included measures capable of capturing the intended effects. Wilson and Cleary80 provide a useful framework that can guide the choice of measures and the interpretation and presentation of results (Figure 1).

Figure 1 Conceptual framework

Source: Wilson IB, Cleary PD. Linking clinical variables with health-related quality of life. A conceptual model of patient outcomes. JAMA. 1995;273:59-65. Reprinted with permission.

Interventions are grounded in some conceptual framework about how the intervention would work and what dimensions of health status would be impacted. The systematic reviewer must examine the conceptual framework of the original work to determine if the study included measurement instruments capable of capturing the intended effects. Wilson and Cleary1 provide a useful framework that can guide the choice of measures and the interpretation and presentation of results. In the Wilson and Cleary Figure, on the extreme left Biological and Physiological variables affect Symptom Status. Symptom Status is also affected by Psychological Supports that is in turn affected by Characteristics of the Environment (at the bottom of the Figure). Similarly, Symptom Status is affected by Symptom Amplification, which in turn is affected by Characteristics of the Individual (at the top of the Figure). Characteristics of the Individual through Personality Motivation affect Functional Status (in the middle of the Figure). Functional Status is also affected by Characteristics of the Environment through Social and Economic Supports. Characteristics of the Environment through Social and Psychological Supports affect General Health Perceptions and Overall Quality of Life (at the extreme right of the Figure). Similarly, Characteristics of the Individual through Values/Preferences affects both General Health Perceptions and Overall Quality of Life. Furthermore, Functional Status directly affects General Health Perceptions which in turn directly affects Overall Quality of Life. Finally, Overall Quality of Life is also affected by Nonmedical Factors. 1 Wilson IB, Cleary PD. Linking clinical variables with health-related quality of life. A conceptual model of patient outcomes. JAMA. 1995;273:59-65.

Another prominent framework is provided by the World Health Organization International Classification of Functioning, Disability, and Health (ICF).81 The ICF focuses on the concepts of impairment, disability, participation, and the physical and social environment surrounding the subject. Like the Wilson and Cleary framework, the ICF can provide guidance to the systematic reviewer about what effects of an intervention and characteristics of the context in which the intervention took place to assess.

## Minimum Important Difference

How to interpret the results of an intervention to prevent functional decline or improve HRQL is a key issue. Is the magnitude of change important? A statistically significant effect may not always translate to an important change from baseline. Thus, one must also consider the clinically important difference (CID), or minimum important difference (MID), defined as: “The smallest difference in score in the outcome of interest that informed patients or informed proxies perceive as important, either beneficial or harmful, and that would lead the patient or clinician to consider a change in management”.82 Guyatt and colleagues suggest the use of the term “patient-important” rather than “clinically important” to focus on the “preeminence of the patient's values and preferences.”83,84

MIDs are estimated using anchor-based or distribution-based approaches.24,85-90 In the anchor-based approach, the change in HRQL score is related to a well-established meaningful measure. The anchor itself must be an independent measure and be readily interpretable—for example, the categories of the New York Heart Association functional classification system or ability to climb a flight of stairs. There must be an appreciable correlation when measured at the same time in the same person between the anchor and the target measure.88 In contrast, the distribution-based approach is based on statistical criteria. It compares the magnitude of change compared to some measure of the variability of scores such as effect size (ES). Similar to evidence on construct validity, evidence on the usefulness of MIDs accumulates and evolves over time. If a guideline on the MID for a measure generates results that are congruent with clinical evidence and evidence from other measures, confidence in the usefulness of that MID increases over time. There is mixed evidence on the extent to which MIDs are context free.

Ware and Keller, using SF-36 data from the Medical Outcomes Study, provided examples of the usefulness of anchor-based approaches.91 The PF scale ranges from 0 to 100. Thirty-two percent of respondents with a score of 40 can walk one block without limitations, a readily interpretable anchor; at a score of 50, 49.7 percent are able to walk a block. A change in PF score of 10 is clearly important. Yet a change of 10 in PF from 80 to 90 implies that 98.8 percent of respondents instead of 98.4 percent of respondents will be able to walk a block. Given that the standard deviation (SD) for the PF scale is 23.3,^45^ a change of 10 is equivalent to an ES of 0.43, moderate in the scheme proposed by Cohen.30 In this example, the anchor-based interpretation is meaningful while the distribution-based interpretation (ES) has the potential to be misleading.

A number of studies report results in which anchor-based and distribution-based approaches provide similar estimates of the threshold for a patient-important difference.89 If a systematic reviewer cannot find evidence in support of an anchor-based criterion for a measure, one default option is to use 1.0 standard error of measurement or 0.5 SD. Nonetheless, anchor-based MIDs that focus on the importance of the magnitude of the change provide a conceptually preferable guide to interpreting results than do distribution-based criteria.92,93

## Absolute or Relative Change?

An advantage of ES and SRM is that they can be used to make comparisons across studies and among measures. However, within a study the stimulus (intervention) is the same so one can compare the absolute magnitude of change among measures that use a common scale such as the conventional scale for preference-based (utility) measures in which 0.00 = dead and perfect health = 1.00. In general, clinicians and systematic reviewers are more interested in the absolute magnitude of change than in the relative magnitude of change expressed in SD units (ES or SRM).

One level of interpretation is to consider if the mean magnitude of change observed in a RCT is patient- or clinically important. More relevant is the proportion of patients achieving no, small, moderate, or large change.88 As Guyatt and colleagues note, mean change can be misleading if, for instance, there is heterogeneity in treatment effect such that an important minority of patients improved moderately while the majority experienced no change.94 The proportion that benefit can then be used to calculate the number needed to treat, the inverse of the absolute risk reduction, which has intuitive appeal to clinicians. Johnston and colleagues discuss an algorithm that allows systematic reviewers to make comparisons across studies using MIDs.95 A related approach focuses on individual-level data and the classification of patients as responders if the change that individual experienced is greater than or equal to a threshold—in a sense, a criterion for a patient-important difference defined at the individual level.2,96

## Observational Data

Although the advantages of using evidence derived large randomized controlled clinical trials are well known, relevant trial data is often sparse or not available to systematic reviewers. Sometimes a reviewer must rely on observational data on the effects of an intervention. It may therefore be useful to compare the trajectory observed in the study to trajectories observed in natural history cohort studies of older adults. Evidence from such cohort studies might also be useful for interpreting results from controlled clinical trials.97 When serving a high-risk population, slowing the rate of decline in functional status or HRQL may be a realistic goal and the maintenance of stability (as opposed to improvement) may be a marker of success.98 Evidence from a natural history cohort can serve as a useful comparator for the results of an intervention tested in an observational study. Such evidence provides an answer to a counterfactual question: what would have happened in the absence of an intervention? Two examples are the longitudinal National Population Survey (NPHS) and Beaver Dam study.

The Statistics Canada NPHS displayed 10-year trends in overall HRQL for a cohort of respondents 40 years and older living in the community at baseline in 1994/95. The rate of decline in HRQL (measured by HUI3) accelerated in respondents aged in their mid-70s. The rate of decline is higher when those who were institutionalized and those who died during the followup period were included in the analyses.99 Data from the NPHS could serve as a benchmark for comparisons.

Another example of a longitudinal natural history cohort is the Beaver Dam study. Begun in 1987-1988 in Beaver Dam, Wisconsin, a cohort of 4,926 respondents 43-84 years old was enrolled.100-102 Respondents have been followed since, most recently surveyed at 15 years of followup (from 2003 to 2005).103 HRQL measures used in the Beaver Dam study included the SF-36, the QWB,104 and the time-trade off.20 The Beaver Dam study provides a rich source of natural history data, and although participants reported a wide range of income levels, its mainly white population (99 percent) may not generalize to the entire U.S.