# Implications for Systematic Reviewers

Systematic reviewers should review the methods of the empirical studies assessing HRQL and functional status in light of the normative study design criteria outlined above in Section 4. But what if not all the criteria are met? For instance, if the existing evidence is based solely or almost exclusively on the basis of condition-specific measures of HRQL, the risk of a false negative result on the effectiveness of the intervention may be lower (specific measures are often more responsive) but the risk of a false positive result (concluding that the net benefits of the intervention are positive) may be higher because of the attenuated ability to detect side effects of treatment, effects which might offset some or even all of the treatment effects. Further, the ability to make broad comparisons will be attenuated because no generic measure was used in the underlying studies. Alternatively, if the underlying research is based mainly on results from generic measures, the risk of a false negative may be higher (generic measures are often less responsive than specific ones) while the risk of a false positive may be lower due to the ability to detect important side effects and the ability to make broad comparisons will be enhanced. Of course, if the generic measure was not carefully selected, floor and/or ceiling effects may attenuate the advantages of generic measures.

If a natural history cohort study that matches the characteristics (or which has a subset of participants who match) of the one being studied in the systematic review is available and that study included suitable measures of HRQL and functional status, then evidence from the observational study can help interpret the results of the intervention study being reviewed. If the match is less than perfect, the systematic reviewer will have to compromise.

Appendix Table 1 provides a brief summary of the relevant measurement properties for a number of widely-used generic measures and a few of the disease-specific measures chosen to illustrate the issues covered in this paper. This is intended to be illustrative, rather than a comprehensive review. Measures based on each of the three major paradigms of HRQL are included in Appendix A, Table 1, the psychometric paradigm (SF-36), the clinimetric paradigm (Chronic Respiratory Questionnaire), and the preference-based/economics/decision science paradigm (HUI3), along with two widely used measures of functional status (activities of daily living; instrumental activities of daily living).