# Summary and Conclusions

Several conclusions emerge. First, randomized trials must include the right patients—those who have enough impairment to make intervention worthwhile, but who are not so ill that an intervention would be unlikely to improve their situation or slow their rate of decline. Second, current HRQL and functional status measures are not always responsive to subtle but important changes in older populations. Third, the older population has substantial heterogeneity in disease progression. Fourth, the natural history of disease in older adults is highly variable. An intervention might slow functional decline, but that can be difficult to demonstrate but nonetheless be important.

As the field of geriatrics embraces these and other recommendations to strengthen the evidence base for evaluating interventions that can prevent functional decline in older adults, systematic reviewers will be able to apply a more rigorous set of criteria that will allow for stronger evidence to guide patient care. Systematic reviewers can employ our framework to ensure that all the challenges inherent in interpreting the literature for this growing population are considered.