# References

1 Tinetti ME, F T, B C. Designing health care for the most common chronic condition–multimorbidity. JAMA. Jun. 20. 2012;307(23):2493-4. [doi: 10.1001/jama.2012.5265]. [pmid: 22797447].
2 U.S.Department of Health and Human Services, FDA, CDER, et al. Guidance for Industry: Patient-Reported Outcome Measures: Use in Medical Product Development to Support Label Claims. Rockville, MD. 2009.
3 Patrick DL, Erickson P. l.s. Health status and health policy: Quality of life in health care evaluation and resource allocation. New York. Oxford University Press. 1993.
4 Starfield B. Basic concepts in population health and health care. J Epidemiol Community Health. Jul. 2001;55(7):452-4. [pmid: 11413173].
5 Fried LP, Tangen CM, Walston J, et al. Frailty in older adults: evidence for a phenotype. J Gerontol A Biol Sci Med Sci. Mar. 2001;56(3):M146-M156. [pmid: 11253156].
6 Guyatt GH, Feeny DH, Patrick DL. Measuring health-related quality of life. Ann Intern Med. Apr. 15. 1993;118(8):622-9. [pmid: 8452328].
7 Garratt A, Schmidt L, Mackintosh A, et al. Quality of life measurement: bibliographic study of patient assessed health outcome measures. BMJ. Jun. 15. 2002;324(7351):1417. [pmid: 12065262].
8 Ware JE Jr., Sherbourne CD. The MOS 36-item short-form health survey (SF-36). 1. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
9 Horsman J, Furlong W, Feeny D, et al. The Health Utilities Index (HUI®): concepts, measurement properties and applications. Health Qual Life Outcomes. Oct. 16. 2003;1(1):54. [pmid: 14613568].
10 Guyatt GH, King DR, Feeny DH, et al. Generic and specific measurement of health-related quality of life in a clinical trial of respiratory rehabilitation. J Clin Epidemiol. Mar. 1999;52(3):187-92. [pmid: 10210235].
11 Wiebe S, Guyatt G, Weaver B, et al. Comparative responsiveness of generic and specific quality-of-life instruments. J Clin Epidemiol. Jan. 2003;56(1):52-60. [pmid: 12589870].
12 Longworth L, Yang Y, Brazier JE, et al. Valuing a vision ‘bolt-on’ item for the EQ-5D. Quality of Life Research. Oct. 1. 2013;21(Supplement 1):53-4.
13 Fayers PM, Machin D. s. Quality of life. The assessment, analysis and interpretation of patient-reported outcomes. West Sussex, England. John Wiley & Sons Ltd. 2007.
14 Beaton DE, Bombardier C, Katz JN, et al. A taxonomy for responsiveness. J Clin Epidemiol. Dec. 2001;54(12):1204-17. [pmid: 11750189].
15 Feeny DH, Furlong W, Mulhern RK, et al. A framework for assessing health-related quality of life among children with cancer. International Journal of Cancer Supplement. 1999;12:2-9.
16 Fayers PM, Hand DJ. Factor analysis, causal indicators and quality of life. Quality of Life Research. Mar. 1997;6(2):139-50. [pmid: 9161114].
17 Eckstrom E, Feeny DH, Walter LC, et al. Individualizing cancer screening in older adults: a narrative review and framework for future research. J Gen Intern Med. Feb. 2013;28(2):292-8. [pmid: 23054920].
18 Feeny D. Health-related quality-of-life data should be regarded as a vital sign. J Clin Epidemiol. Jul. 2013;66(7):706-9. [pmid: 23523549].
19 Torrance GW. Measurement of health state utilities for economic appraisal. J Health Econ. Mar. 1986;5(1):1-30. [pmid: 10311607].
20 Torrance GW, Thomas WH, Sackett DL. A utility maximization model for evaluation of health care programs. Health Serv Res. 1972;7(2):118-33. [pmid: 5044699].
21 Rabin R, de Charro F. EQ-5D: A measure of health status from the EuroQol Group. Ann Med. Jul. 2001;33(5):337-43. [pmid: 11491192].
22 Feeny DH. Preference-based measures: Utility and quality-adjusted life years. Fayers P, Hays R, editors. Assessing Quality of Life in Clinical Trials. Second ed. Oxford. Oxford University Press. 2005:405-29.
23 Feeny DH. The roles for preference-based measures in support of cancer research and policy. Lipscomb J, Gotay CC, Snyder C, editors. Assessment in Cancer: Measures, Methods, and Applications. New York. Cambridge University Press. 2005:69-92.
24 Revicki DA, Osoba D, Fairclough D, et al. Recommendations on health-related quality of life research to support labeling and promotional claims in the United States. Qual Life Res. 2000;9(8):887-900. [pmid: 11284208].
25 Mokkink LB, Terwee CB, Patrick DL, et al. The COSMIN checklist for assessing the methodological quality of studies on measurement properties of health status measurement instruments: an international Delphi study. Qual Life Res. May. 2010;19(4):539-49. [pmid: 20169472].
26 Mokkink LB, Terwee CB, Patrick DL, et al. The COSMIN study reached international consensus on taxonomy, terminology, and definitions of measurement properties for health-related patient-reported outcomes. J Clin Epidemiol. Jul. 2010;63(7):737-45. [pmid: 20494804].
27 Mokkink LB, Terwee CB, Knol DL, et al. The COSMIN checklist for evaluating the methodological quality of studies on measurement properties: a clarification of its content. BMC Med Res Methodol. Mar. 18. 2010;10:22. [pmid: 20298572].
28 The Criteria Committee of the New York Heart Association. Diseases of the Heart and Blood Vessels: Nomenclature and Criteria for Diagnosis. Boston, Mass. Little Brown. 1964.
29 Terwee CB, Dekker FW, Wiersinga WM, et al. On assessing responsiveness of health-related quality of life instruments: guidelines for instrument evaluation. Qual Life Res. Jun. 2003;12(4):349-62. [pmid: 12797708].
30 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, New Jersey. Lawrence Erlbaum Associates. 1988.
31 Norman GR, Wyrwich KW, Patrick DL. The mathematical relationship among different forms of responsiveness coefficients. Qual Life Res. Jun. 2007;16(5):815-22. [pmid: 17351823].
32 Idler EL, Kasl SV, Lemke JH. Self-evaluated health and mortality among the elderly in New Haven, Connecticut, and Iowa and Washington counties, Iowa, 1982-1986. Am J Epidemiol. Jan. 1990;131(1):91-103. [pmid: 2293757].
33 Idler EL, Kasl SV. Self-ratings of health: do they also predict change in functional ability?. J Gerontol B Psychol Sci Soc Sci. Nov. 1995;50(6):S344-53. [pmid: 7583813].
34 Idler EL, Russell LB, Davis D. Survival, functional limitations, and self-rated health in the NHANES I Epidemiologic Follow-up Study, 1992. First National Health and Nutrition Examination Survey. Am J Epidemiol. Nov. 1. 2000;152(9):874-83. [pmid: 11085400].
35 Idler EL, Benyamini Y. Self-rated health and mortality: A review of twenty-seven community studies. J Health Soc Behav. 1997;38(1):21-37. [pmid: 9097506].
36 Benjamins MR, Hummer RA, Eberstein IW, et al. Self-reported health and adult mortality risk: an analysis of cause-specific mortality. Soc Sci Med. Sep. 2004;59(6):1297-306. [pmid: 15210100].
37 Kaplan MS, Berthelot JM, Feeny DH, et al. The predictive validity of two measures of health-related quality of life: mortality in a longitudinal population-based study. Qual Life Res. Nov. 2007;16(9):1539-46. [pmid: 17899447].
38 Diehr P, Williamson J, Burke GL, et al. The aging and dying processes and the health of older adults. J Clin Epidemiol. Mar. 2002;55(3):269-78. [pmid: 11864798].
39 Diehr P, Williamson J, Patrick DL, et al. Patterns of self-rated health in older adults before and after sentinel health events. J Am Geriatr Soc. Jan. 2001;49(1):36-44. [pmid: 11207840].
40 Bjorner JB, Fayers P, Idler EL. Self-rated health. Fayers P, Hays R, editors. Assessing quality of life in clinical trials: Methods and Practice. 2nd ed. New York. Oxford University Press. 2005:309-23.
41 DeSalvo KB, Bloser N, Reynolds K, et al. Mortality prediction with a single general self-rated health question. a meta-analysis. J Gen Intern Med. Mar. 2006;21(3):267-75. [pmid: 16336622].
42 Terwee CB, Mokkink LB, Knol DL, et al. Rating the methodological quality in systematic reviews of studies on measurement properties: a scoring system for the COSMIN checklist. Qual Life Res. May. 2012;20(4):651-7. [doi: 10.1007/s11136-011-9960-1]. [pmid: 21732199].
43 Haywood K, Garratt AM, Schmidt L, et al. Health status and quality of life in older people. A structured review of patient-reported health instruments. Report to the Department of Health April 2004. National Centre for Health Outcomes Development. 2004.
44 Haywood KL, Garratt AM, Fitzpatrick R. Older people specific health status and quality of life: a structured review of self-assessed instruments. J Eval Clin Pract. Aug. 2005;11(4):315-27. [pmid: 16011644].
45 Ware JE. The SF-36 Health Survey. Quality of Life and Pharmacoeconomics in Clinical Trials. Second ed. Philadelphia. Lippincott-Raven. 1996:337-45.
46 Feeny DH, Furlong W, Torrance GW, et al. Multi-attribute and single-attribute utility functions for the health utilities index mark 3 system. Med Care. Feb. 2002;40(2):113-28. [pmid: 11802084].
47 Kaplan RM, Bush JW, Berry CC. Health status: types of validity and the index of well-being. Health Serv Res. 1976;11(4):478-507. [pmid: 1030700].
48 Kaplan RM, Anderson JP. The general health policy model: an integrated approach. Spilker B, editor. Quality of Life and Pharmacoeconomics in Clinical Trials. Second ed. Philadelphia. Lippincott-Raven Press. 1996:309-22.
49 Brazier JE, Walters SJ, Nicholl JP, et al. Using the SF-36 and Euroqol on an elderly population. Qual Life Res. Apr. 1996;5(2):195-204. [pmid: 8998488].
50 McHorney CA, Ware JE Jr., Lu JF, et al. The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Med Care. Jan. 1994;32(1):40-66. [pmid: 8277801].
51 Andresen EM, Bowley N, Rothenberg BM, et al. Test-retest performance of a mailed version of the Medical Outcomes Study 36-Item Short-Form Health Survey among older adults. Med Care. Dec. 1996;34(12):1165-70. [pmid: 8962582].
52 Naglie G, Tomlinson G, Tansey C, et al. Utility-based quality of life measures in Alzheimer's disease. Qual Life Res. May. 15. 2006;15(4):631-43. [pmid: 16688496].
53 Bosch JL, Hunink MG. Comparison of the Health Utilities Index Mark 3 (HUI3) and the EuroQol EQ-5D in patients treated for intermittent claudication. Qual Life Res. 2000;9(6):591-601. [pmid: 11236850].
54 Brazier J, Roberts J, Tsuchiya A, et al. A comparison of the EQ-5D and SF-6D across seven patient groups. Health Econ. Sep. 2004;13(9):873-84. [doi: 10.1002/hec.866]. [pmid: 15362179].
55 Feeny DH, Wu L, Eng K. Comparing short form 6D, standard gamble, and Health Utilities Index Mark 2 and Mark 3 utility scores: results from total hip arthroplasty patients. Qual Life Res. Dec. 2004;13(10):1659-70. [pmid: 15651537].
56 Grieve R, Grishchenko M, Cairns J. SF-6D versus EQ-5D: reasons for differences in utility scores and impact on reported cost-utility. Eur J Health Econ. Mar. 9. 2008;10(1):15-23. [pmid: 18327677].
57 Guo N, Marra CA, Marra F, et al. Health state utilities in latent and active tuberculosis. Value in Health. Dec. 2008;11(7):1154-61. [pmid: 18489493].
58 Harrison MJ, Davies LM, Bansback NJ, et al. The comparative responsiveness of the EQ-5D and SF-6D to change in patients with inflammatory arthritis. Qual Life Res. Nov. 2009;18(9):1195-205. [pmid: 19777373].
59 Hatoum HT, Brazier JE, Akhras KS. Comparison of the HUI3 with the SF-36 preference based SF-6D in a clinical trial setting. Value in Health. Sep. 2004;7(5):602-9. [pmid: 15367255].
60 Kopec JA, Willison KD. A comparative review of four preference-weighted measures of health-related quality of life. J Clin Epidemiol. Apr. 2003;56(4):317-25. [pii: S0895435602006091]. [pmid: 12767408].
61 Longworth L, Bryan S. An empirical comparison of EQ-5D and SF-6D in liver transplant patients. Health Econ. Dec. 2003;12(12):1061-7. [pmid: 14673814].
62 O'Brien BJ, Spath M, Blackhouse G, et al. A view from the bridge: agreement between the SF-6D utility algorithm and the Health Utilities Index. Health Econ. Nov. 2003;12(11):975-81. [pmid: 14601159].
63 Pickard AS, Johnson JA, Feeny DH. Responsiveness of generic health-related quality of life measures in stroke. Qual Life Res. Feb. 2005;14(1):207-19. [pmid: 15789955].
64 Suarez-Almazor ME, Kendall C, Johnson JA, et al. Use of health status measures in patients with low back pain in clinical settings. Comparison of specific, generic and preference-based instruments. Rheumatology (Oxford). Jul. 2000;39(7):783-90. [pmid: 10908699].
65 Szende A, Svensson K, Stahl E, et al. Psychometric and utility-based measures of health status of asthmatic patients with different disease control level. Pharmacoeconomics. 2004;22(8):537-47. [pii: 2285]. [pmid: 15217309].
66 Szende A, Leidy NK, Stahl E, et al. Estimating health utilities in patients with asthma and COPD: evidence on the performance of EQ-5D and SF-6D. Qual Life Res. Mar. 2009;18(2):267-72. [doi: 10.1007/s11136-008-9429-z]. [pmid: 19105049].
67 Taylor SJ, Taylor AE, Foy MA, et al. Responsiveness of common outcome measures for patients with low back pain. Spine. Sep. 1. 1999;24(17):1805-12. [pmid: 10488511].
68 Brazier J, Roberts J, Deverill M. The estimation of a preference-based measure of health from the SF-36. J Health Econ. Mar. 2002;21(2):271-92. [pmid: 11939242].
69 Luo N, Chew LH, Fong KY, et al. A comparison of the EuroQol-5D and the Health Utilities Index mark 3 in patients with rheumatic disease. J Rheumatol. Oct. 2003;30(10):2268-74. [pmid: 14528528].
70 Klassen A, Fitzpatrick R, Jenkinson C, et al. Contrasting evidence of the effectiveness of cosmetic surgery from two health related quality of life measures. J Epidemiol Community Health. Jul. 1999;53(7):440-1. [pmid: 10492741].
71 Dobscha SK, Corson K, Perrin NA, et al. Collaborative care for chronic pain in primary care: a cluster randomized trial. JAMA. Mar. 25. 2009;301(12):1242-52. [pmid: 19318652].
72 Haywood KL, Garratt AM, Lall R, et al. EuroQol EQ-5D and condition-specific measures of health outcome in women with urinary incontinence: reliability, validity and responsiveness. Qual Life Res. Apr. 2008;17(3):475-83. [doi: 10.1007/s11136-008-9311-z]. [pmid: 18274881].
73 Walters SJ, Morrell CJ, Dixon S. Measuring health-related quality of life in patients with venous leg ulcers. Qual Life Res. Jun. 1999;8(4):327-36. [pmid: 10472165].
74 Pickard AS, De Leon MC, Kohlmann T, et al. Psychometric comparison of the standard EQ-5D to a 5 level version in cancer patients. Med Care. Mar. 2007;45(3):259-63. [pmid: 17304084].
75 Fryback DG, Dunham NC, Palta M, et al. US norms for six generic health-related quality-of-life indexes from the National Health Measurement study. Med Care. Dec. 2007;45(12):1162-70. [pmid: 18007166].
76 Cherepanov D, Palta M, Fryback DG. Underlying Dimensions of the Five Health-Related Quality-of-Life Measures Used in Utility Assessment: Evidence From the National Health Measurement Study. Med Care. Aug. 2010;48(8):718-25. [pmid: 20613664].
77 Magaziner J, Simonsick EM, Kashner TM, et al. Patient-proxy response comparability on measures of patient health and functional status. J Clin Epidemiol. 1988;41(11):1065-74. [pmid: 3204417].
78 Sneeuw KC, Aaronson NK, Sprangers MA, et al. Evaluating the quality of life of cancer patients: assessments by patients, significant others, physicians and nurses. Br J Cancer. Sep. 1999;81(1):87-94. [pmid: 10487617].
79 Jones CA, Feeny DH. Agreement between patient and proxy responses of health-related quality of life after hip fracture. J Am Geriatr Soc. Jul. 2005;53(7):1227-33. [pmid: 16108944].
80 Wilson IB, Cleary PD. Linking clinical variables with health-related quality of life. A conceptual model of patient outcomes. JAMA. Jan. 4. 1995;273(1):59-65. [pmid: 7996652].
81 World Health Organization. International Classification of Functioning, Disability and Health. Geneva. World Health Organization. 2001. June 21, 2013.
82 Schunemann HJ, Puhan M, Goldstein R, et al. Measurement properties and interpretability of the Chronic respiratory disease questionnaire (CRQ). COPD. Mar. 2005;2(1):81-9. [pmid: 17136967].
83 Guyatt G, Montori V, Devereaux PJ, et al. Patients at the center: in our practice, and in our use of language. ACP J Club. Jan. 2004;140(1):A11-A12. [pii: ACPJC-2004-140-1-A11]. [pmid: 14711297].
84 Schunemann HJ, Guyatt GH. Commentary--goodbye M(C)ID! Hello MID, where do you come from?. Health Serv Res. Apr. 2005;40(2):593-7. [pii: HESR374]. [doi: 10.1111/j.1475-6773.2005.00374.x]. [pmid: 15762909].
85 Revicki D, Hays RD, Cella D, et al. Recommended methods for determining responsiveness and minimally important differences for patient-reported outcomes. J Clin Epidemiol. Feb. 2008;61(2):102-9. [pmid: 18177782].
86 Hays RD, Farivar SS, Liu H. Approaches and recommendations for estimating minimally important differences for health-related quality of life measures. COPD. Mar. 2005;2(1):63-7. [pmid: 17136964].
87 Leidy NK, Wyrwich KW. Bridging the gap: using triangulation methodology to estimate minimal clinically important differences (MCIDs). COPD. Mar. 2005;2(1):157-65. [pmid: 17136977].
88 Guyatt GH, Osoba D, Wu AW, et al. Methods to explain the clinical significance of health status measures. Mayo Clin Proc. Apr. 2002;77(4):371-83. [pmid: 11936935].
89 Wyrwich KW, Bullinger M, Aaronson N, et al. Estimating clinically significant differences in quality of life outcomes. Qual Life Res. Mar. 2005;14(2):285-95. [pmid: 15892420].
90 Wyrwich KW, Norquist JM, Lenderking WR, et al. Methods for interpreting change over time in patient-reported outcome measures. Qual Life Res. Apr. 2013;22(3):475-83. [pmid: 22528240].
91 Ware JE, Keller SD. Interpreting general health measures. Spilker BF, editor. Quality of Life and Pharmacoeconomics in Clinical Trials. Second ed. Philadelphia. Lippincott-Raven. 1996:445-60.
92 de Vet HC, Terwee CB, Ostelo RW, et al. Minimal changes in health status questionnaires: distinction between minimally detectable change and minimally important change. Health Qual Life Outcomes. Aug. 22. 2006;4:54. [pii: 1477-7525-4-54]. [doi: 10.1186/1477-7525-4-54]. [pmid: 16925807].
93 Turner D, Schunemann HJ, Griffith LE, et al. The minimal detectable change cannot reliably replace the minimal important difference. J Clin Epidemiol. Jul. 2010;63(1):28-36. [pmid: 19800198].
94 Guyatt GH, Juniper EF, Walter SD, et al. Interpreting treatment effects in randomised trials. BMJ. Feb. 28. 1998;316(7132):690-3. [pmid: 9522799].
95 Johnston BC, Thorlund K, Schunemann HJ, et al. Improving the interpretation of quality of life evidence in meta-analyses: the application of minimal important difference units. Health Qual Life Outcomes. 2010;8:116. [pmid: 20937092].
96 McLeod LD, Coon CD, Martin SA, et al. Interpreting patient-reported outcome results: US FDA guidance and emerging methods. Expert Rev Pharmacoecon Outcomes Res. Apr. 2011;11(2):163-9. [pmid: 21476818].
97 Norris SL, High K, Gill TM, et al. Health care for older Americans with multiple chronic conditions: a research agenda. J Am Geriatr Soc. Jan. 2008;56(1):149-59. [pmid: 18047493].
98 Klein S, McCarthy D. CareOregon: Transforming the role of a Medicaid Health Plan from payer to partner. 2010;50.
99 Orpana HM, Ross N, Feeny D, et al. The natural history of health-related quality of life: a 10-year cohort study. Health Reports. Mar. 2009;20(1):1-7.
100 Klein R, Klein BE, Linton KL, et al. The Beaver Dam Eye Study: visual acuity. Ophthalmology. Aug. 1991;98(8):1310-5. [pmid: 1923372].
101 Klein R, Klein BE, Moss SE. Age-related eye disease and survival. The Beaver Dam Eye Study. Arch Ophthalmol. Mar. 1995;113(3):333-9. [pmid: 7887847].
102 Fryback DG, Dasbach EJ, Klein R, et al. The Beaver Dam Health Outcomes Study: initial catalog of health-state quality factors. Med Decis Making. Apr. 1993;13(2):89-102. [pmid: 8483408].
103 Klein R, Klein BE, Lee KE, et al. Changes in visual acuity in a population over a 15-year period: The Beaver Dam Eye Study. Am J Ophthalmol. Oct. 2006;142(4):539-49. [pmid: 17011842].
104 Patrick DL, Bush JW, Chen MM. Methods for measuring levels of well-being for a health status index. Health Serv Res. 1973;8(3):228-45. [pmid: 4761617].
105 Feinstein AR. Benefits and obstacles for development of health status assessment measures in clinical settings. Med Care. May. 1992;30(5 Suppl):MS50-MS56. [pmid: 1583941].
106 Osoba D, King M. Meaningful differences. Fayers P, Hays R, editors. Assessing Quality of Life in Clinical Trials. Second ed. Oxford. Oxford University Press. 2005:243-57.
107 Feeny D, Spritzer K, Hays RD, et al. Agreement about Identifying Patients Who Change over Time: Cautionary Results in Cataract and Heart Failure Patients. Med Decis Making. 2012;32(2):273-86. [pii: 0272989X11418671]. [doi: 10.1177/0272989X11418671]. [pmid: 22009666].
108 Feeny D. Standardization and regulatory guidelines may inhibit science and reduce the usefulness of analyses based on the application of preference-based measures for policy decisions. Med Decis Making. Apr. 2013;33(3):316-9. [pmid: 23184461].
109 Velikova G, Booth L, Smith AB, et al. Measuring quality of life in routine oncology practice improves communication and patient well-being: a randomized controlled trial. J Clin Oncol. Feb. 15. 2004;22(4):714-24. [doi: 10.1200/JCO.2004.06.078]. [pii: JCO.2004.06.078]. [pmid: 14966096].
110 Santana MJ, Feeny D, Johnson JA, et al. Assessing the use of health-related quality of life measures in the routine clinical care of lung-transplant patients. Qual Life Res. Apr. 2010;19(3):371-9. [pmid: 20146009].
111 Abernethy AP, Etheredge LM, Ganz PA, et al. Rapid-learning system for cancer care. J Clin Oncol. Sep. 20. 2010;28(27):4268-74. [pmid: 20585094].
112 Tinetti ME, Studenski SA. Comparative Effectiveness Research and Patients with Multiple Chronic Conditions. N Engl J Med. Jun. 22. 2011;364(26):2478-81. [doi: 10.1056/NEJMp1100535]. [pmid: 21696327].
113 Cella D, Gershon R, Lai JS, et al. The future of outcomes measurement: item banking, tailored short-forms, and computerized adaptive assessment. Qual Life Res. 2007;16(Suppl 1):133-41. [pmid: 17401637].
114 Cella D, Yount S, Rothrock N, et al. The Patient-Reported Outcomes Measurement Information System (PROMIS): progress of an NIH Roadmap cooperative group during its first two years. Med Care. May. 2007;45(5 Suppl 1):S3-S11. [pmid: 17443116].
115 Fries JF, Bruce B, Cella D. The promise of PROMIS: using item response theory to improve assessment of patient-reported outcomes. Clin Exp Rheumatol. Sep. 2005;23(5 Suppl 39):S53-S57. [pmid: 16273785].
116 Staquet M, Berzon R, Osoba D, et al. Guidelines for reporting results of quality of life assessments in clinical trials. Qual Life Res. Oct. 1996;5(5):496-502. [pmid: 8973129].
117 Lee CW, Chi KN. The standard of reporting of health-related quality of life in clinical cancer trials. J Clin Epidemiol. May. 2000;53(5):451-8. [pmid: 10812316].
118 Brundage M, Bass B, Davidson J, et al. Patterns of reporting health-related quality of life outcomes in randomized clinical trials: implications for clinicians and quality of life researchers. Qual Life Res. Nov. 26. 2010;20(5):653-64. [pmid: 21110123].
119 Brundage M, Bass B, Jolie R, et al. A knowledge translation challenge: clinical use of quality of life data from cancer clinical trials. Qual Life Res. Jan. 29. 2011;20(7):979-85. [pmid: 21279446].
120 Calvert M, Blazeby J, Altman DG, et al. Reporting of patient-reported outcomes in randomized trials: the CONSORT PRO extension. JAMA. Feb. 27. 2013;309(8):814-22. [pmid: 23443445].
121 Guyatt G, Feeny D, Patrick D. Glossary. Control Clin Trials. Aug. 1991;12(4 Suppl 1):274S-80S.
122 Osoba D, editor. The effect of cancer on quality of life. Boca Raton, FL. CRC Press Inc. 1991.
123 Glossary: Health Outcomes Methodology. Medical Care. 2000;38(9 Suppl):II7-II13. [pmid: 10982086].
124 McDowell I. Measuring health: a guide to rating scales and questionnaires. New York, NY. Oxford University Press. 2006.
125 Sikkes SA, de Lange-de Klerk ES, Pijnenburg YA, et al. A systematic review of Instrumental Activities of Daily Living scales in dementia: room for improvement. J Neurol Neurosurg Psychiatry. Jan. 2009;80(1):7-12. [pmid: 19091706].
126 Guyatt GH, Berman LB, Townsend M, et al. A measure of quality of life for clinical trials in chronic lung disease. Thorax. Oct. 1987;42(10):773-8. [pmid: 3321537].
127 Haywood K, Garratt AM, Schmidt L, et al. Health status and quality of life in older people. A structured review of patient-reported health instruments. National Centre for Health Outcomes Development. 2004.
128 Laake K, Laake P, Ranhoff AH, et al. The Barthel ADL index: factor structure depends upon the category of patient. Age Ageing. Sep. 1995;24(5):393-7. [pmid: 8669341].
129 de Morton NA, Keating JL, Davidson M. Rasch analysis of the barthel index in the assessment of hospitalized older patients after admission for an acute medical condition. Arch Phys Med Rehabil. Apr. 2008;89(4):641-7. [pmid: 18373993].
130 Hsueh IP, Lin JH, Jeng JS, et al. Comparison of the psychometric characteristics of the functional independence measure, 5 item Barthel index, and 10 item Barthel index in patients with stroke. J Neurol Neurosurg Psychiatry. Aug. 2002;73(2):188-90. [pmid: 12122181].
131 Hajiro T, Nishimura K, Tsukino M, et al. Comparison of discriminative properties among disease-specific questionnaires for measuring health-related quality of life in patients with chronic obstructive pulmonary disease. Am J Respir Crit Care Med. Mar. 1998;157(3 Pt 1):785-90. [pmid: 9517591].
132 Lacasse Y, Wong E, Guyatt G. A systematic overview of the measurement properties of the Chronic Respiratory Questionnaire. Canadian Respiratory Journal. 1997;4(3):131-9.
133 Sainsbury A, Seebass G, Bansal A, et al. Reliability of the Barthel Index when used with older people. Age Ageing. May. 2005;34(3):228-32. [pmid: 15863408].
134 Wyller TB, Sveen U, Bautz-Holter E. The Barthel ADL index one year after stroke: comparison between relatives' and occupational therapist's scores. Age Ageing. Sep. 1995;24(5):398-401. [pmid: 8669342].
135 Ranhoff AH, Laake K. The Barthel ADL index: scoring by the physician from patient interview is not reliable. Age Ageing. May. 1993;22(3):171-4. [pmid: 8503312].
136 Hsueh IP, Lee MM, Hsieh CL. Psychometric characteristics of the Barthel activities of daily living index in stroke patients. J Formos Med Assoc. Aug. 2001;100(8):526-32. [pmid: 11678002].
137 Hung SY, Pickard AS, Witt WP, et al. Pain and depression in caregivers affected their perception of pain in stroke patients. J Clin Epidemiol. Sep. 2007;60(9):963-70. [pmid: 17689813].
138 Pickard AS, Johnson JA, Feeny DH, et al. Agreement between patient and proxy assessments of health-related quality of life after stroke using the EQ-5D and Health Utilities Index. Stroke. Feb. 2004;35(2):607-12. [pmid: 14726549].
139 Dorman P, Slattery J, Farrell B, et al. Qualitative comparison of the reliability of health status assessments with the EuroQol and SF-36 questionnaires after stroke. United Kingdom Collaborators in the International Stroke Trial. Stroke. Jan. 1998;29(1):63-8. [pmid: 9445330].
140 Coons SJ, Rao S, Keininger DL, et al. A comparative review of generic quality-of-life instruments. Pharmacoeconomics. Jan. 2000;17(1):13-35. [pmid: 10747763].
141 Fisk JD, Brown MG, Sketris IS, et al. A comparison of health utility measures for the evaluation of multiple sclerosis treatments. J Neurol Neurosurg Psychiatry. Jan. 2005;76(1):58-63. [pmid: 15607996].
142 Marra CA, Rashidi AA, Guh D, et al. Are indirect utility measures reliable and responsive in rheumatoid arthritis patients?. Qual Life Res. Jun. 2005;14(5):1333-44. [pmid: 16047508].
143 Thoma A, Sprague S, Veltri K, et al. Methodology and measurement properties of health-related quality of life instruments: a prospective study of patients undergoing breast reduction surgery. Health Qual Life Outcomes. Jul. 22. 2005;3:44. [pmid: 16042775].
144 Wiebe S, Eliasziw M, Matijevic S. Changes in quality of life in epilepsy: how large must they be to be real?. Epilepsia. Jan. 2001;42(1):113-8. [pmid: 11207794].
145 Boyle MH, Furlong W, Feeny D, et al. Reliability of the Health Utilities Index--Mark III used in the 1991 cycle 6 Canadian General Social Survey Health Questionnaire. Quality of Life Research. Jun. 1995;4(3):249-57. [pmid: 7613535].
146 Wijkstra PJ, TenVergert EM, Van AR, et al. Reliability and validity of the chronic respiratory questionnaire (CRQ). Thorax. May. 1994;49(5):465-7. [pmid: 8016767].
147 Martin LL. Validity and reliability of a quality-of-life instrument: the chronic respiratory disease questionnaire. Clin Nurs Res. May. 1994;3(2):146-56. [pmid: 8173519].
148 Green J, Forster A, Young J. A test-retest reliability study of the Barthel Index, the Rivermead Mobility Index, the Nottingham Extended Activities of Daily Living Scale and the Frenchay Activities Index in stroke patients. Disabil Rehabil. Oct. 15. 2001;23(15):670-6. [pmid: 11720117].
149 Jones CA, Feeny D, Eng K. Test-retest reliability of health utilities index scores: evidence from hip fracture. Int J Technol Assess Health Care. 2005;21(3):393-8. [pmid: 16110720].
150 Naglie G, Tomlinson G, Tansey C, et al. Utility-based quality of life measures in Alzheimer's disease. Qual Life Res. May. 15. 2006;15(4):631-43. [pmid: 16688496].
151 Jones CA, Pohar SL, Warren S, et al. The burden of multiple sclerosis: a community health survey. Health Qual Life Outcomes. 2008;6:1. [pmid: 18179687].
152 Wilkinson PR, Wolfe CD, Warburton FG, et al. Longer term quality of life and outcome in stroke patients: is the Barthel index alone an adequate measure of outcome?. Qual Health Care. Sep. 1997;6(3):125-30. [pmid: 10173769].
153 Barberger-Gateau P, Commenges D, Gagnon M, et al. Instrumental activities of daily living as a screening tool for cognitive impairment and dementia in elderly community dwellers. J Am Geriatr Soc. Nov. 1992;40(11):1129-34. [pmid: 1401698].
154 Hancock P, Larner AJ. The diagnosis of dementia: diagnostic accuracy of an instrument measuring activities of daily living in a clinic-based population. Dement Geriatr Cogn Disord. 2007;23(3):133-9. [pmid: 17170525].
155 Grutters JP, Joore MA, van der HF, et al. Choosing between measures: comparison of EQ-5D, HUI2 and HUI3 in persons with hearing complaints. Quality of Life Research. Oct. 2007;16(8):1439-49. [pmid: 17647093].
156 Neumann PJ, Kuntz KM, Leon J, et al. Health utilities in Alzheimer's disease: a cross-sectional study of patients and caregivers. Med Care. Jan. 1999;37(1):27-32. [pmid: 10413389].
157 Sawatzky R, Liu-Ambrose T, Miller WC, et al. Physical activity as a mediator of the impact of chronic conditions on quality of life in older adults. Health Qual Life Outcomes. 2007;5:68. [pmid: 18093310].
158 Robert SA, Cherepanov D, Palta M, et al. Socioeconomic status and age variations in health-related quality of life: results from the national health measurement study. J Gerontol B Psychol Sci Soc Sci. May. 2009;64(3):378-89. [pmid: 19307286].
159 Huguet N, Kaplan MS, Feeny D. Socioeconomic status and health-related quality of life among elderly people: results from the Joint Canada/United States Survey of Health. Soc Sci Med. Feb. 2008;66(4):803-10. [pmid: 18155337].
160 Wexler DJ, Grant RW, Wittenberg E, et al. Correlates of health-related quality of life in type 2 diabetes. Diabetologia. Jul. 2006;49(7):1489-97. [pmid: 16752167].
161 Garster NC, Palta M, Sweitzer NK, et al. Measuring health-related quality of life in population-based studies of coronary heart disease: comparing six generic indexes and a disease-specific proxy score. Qual Life Res. Sep. 16. 2009;18(9):1239-47. [pmid: 19760103].
162 Pohar SL, Jones CA. The burden of Parkinson disease (PD) and concomitant comorbidities. Arch Gerontol Geriatr. Sep. 2009;49(2):317-21. [pii: S0167-4943(08)00229-X]. [doi: 10.1016/j.archger.2008.11.006]. [pmid: 19135266].
163 Harper R, Brazier JE, Waterhouse JC, et al. Comparison of outcome measures for patients with chronic obstructive pulmonary disease (COPD) in an outpatient setting. Thorax. Oct. 1997;52(10):879-87. [pmid: 9404375].
164 Guyatt GH, Townsend M, Keller J, et al. Measuring functional status in chronic lung disease: conclusions from a randomized control trial. Respir Med. Jul. 1989;83(4):293-7. [pmid: 2692093].
165 Wallace D, Duncan PW, Lai SM. Comparison of the responsiveness of the Barthel Index and the motor component of the Functional Independence Measure in stroke: the impact of using different methods for measuring responsiveness. J Clin Epidemiol. Sep. 2002;55(9):922-8. [pmid: 12393081].
166 van der Putten JJ, Hobart JC, Freeman JA, et al. Measuring change in disability after inpatient rehabilitation: comparison of the responsiveness of the Barthel index and the Functional Independence Measure. J Neurol Neurosurg Psychiatry. Apr. 1999;66(4):480-4. [pmid: 10201420].
167 Ware JE. SF-36 health survey update. 2011. http://www.sf-35.org/tools/sf35.shtml#MODEL. November 2, 2010.
168 O'Mahony PG, Rodgers H, Thomson RG, et al. Is the SF-36 suitable for assessing health status of older stroke patients?. Age Ageing. Jan. 1998;27(1):19-22. [pmid: 9504362].
169 O'Connor RJ, Cano SJ, Thompson AJ, et al. Exploring rating scale responsiveness: does the total score reflect the sum of its parts?. Neurology. May. 25. 2004;62(10):1842-4. [pmid: 15159490].
170 Wellwood I, Dennis MS, Warlow CP. A comparison of the Barthel Index and the OPCS disability instrument used to measure outcome after acute stroke. Age Ageing. Jan. 1995;24(1):54-7. [pmid: 7762463].
171 Duncan PW, Samsa GP, Weinberger M, et al. Health status of individuals with mild stroke. Stroke. Apr. 1997;28(4):740-5. [pmid: 9099189].
172 Balu S. Differences in psychometric properties, cut-off scores, and outcomes between the Barthel Index and Modified Rankin Scale in pharmacotherapy-based stroke trials: systematic literature review. Curr Med Res Opin. Jun. 2009;25(6):1329-41. [pmid: 19419341].
173 Wyrwich KW, Tierney WM, Babu AN, et al. A comparison of clinically important differences in health-related quality of life for patients with chronic lung disease, asthma, or heart disease. Health Serv Res. Apr. 2005;40(2):577-91. [pmid: 15762908].
174 Ware JE, Keller SD. Interpreting general health measures. Spilker BF, editor. Quality of Life and Pharmacoeconomics in Clinical Trials. Second ed. Philadelphia. Lippincott-Raven. 2010:445-60.
175 Hsieh YW, Wang CH, Wu SC, et al. Establishing the minimal clinically important difference of the Barthel Index in stroke patients. Neurorehabil Neural Repair. May. 2007;21(3):233-8. [pmid: 17351082].
176 Bowling A. Measuring Health: A Guide to Rating Scales and Questionnaires. Buckingham, UK. Open University Press. 2001.
177 Redelmeier DA, Guyatt GH, Goldstein RS. Assessing the minimal important difference in symptoms: a comparison of two techniques. J Clin Epidemiol. Nov. 1996;49(11):1215-9. [pmid: 8892486].
178 Hobart JC, Cano SJ, Thompson AJ. Effect sizes can be misleading: is it time to change the way we measure change?. J Neurol Neurosurg Psychiatry. Sep. 2010;81(9):1044-8. [pmid: 20627964].