# Introduction

A key to improving the health of our aging population is developing evidence-based guidelines that can inform best practices at the patient, health system, and policy levels. The field of systematic review has evolved to include sophisticated meta-analytic techniques and highly structured evidence reviews. However, evidence-based guidelines have focused largely on single diseases and general populations, and have left gaps in recommendations for older, functionally impaired populations with multiple morbidities.1 Systematic reviewers have often focused on objective outcomes such as mortality, with less consideration to health-related quality of life (HRQL) and functional outcomes. Yet, these patient reported outcomes could be very useful—both to evaluate the effectiveness of interventions to improve health in older adults, and as a means of defining risk status and identifying important subgroups for analyses.

This paper will identify important issues in using evidence from these measures in systematic reviews, and interpret these issues for clinicians, researchers, and systematic reviewers. In Section 2, we briefly define important relevant measurement properties and summarize evidence on the measurement properties of common measures used to assess patient-reported outcomes, including the classification of measures, the populations studied, reliability, validity, special considerations for older adults, floor and ceiling effects, and using proxy respondents. Section 3 focuses on how to interpret functional status and HRQL evidence. Sections 4 and 5 discuss implications for researchers and systematic reviewers; Section 6 provides a summary and conclusions.

The paper highlights several challenges for systematic reviewers in synthesizing evidence to improve HRQL and reduce functional decline in older adults. First, the evidence on how well various measures perform in studies of older adults is often sparse. Second, because some older adults are not able to respond on their own behalf, investigators must often rely on family members and friends acting as proxy respondents. Third, evidence on the magnitude of change that is patient-important to older adults is often lacking. Finally, floor and ceiling effects often attenuate the usefulness of many measures.